# Introduction

## Background

### Context

Sepsis is a serious condition with high morbidity and mortality for which clinical diagnostic criteria lack sensitivity and specificity. Early initiation of appropriate antibiotics and goal-directed therapies reduce mortality. Conversely, overuse and misuse of antibiotics, including continuing antibiotics longer than necessary for cure can result in adverse events and add to the increasing problem of antibiotic resistance. Although critically ill patients in the intensive care units (ICU) have higher morbidity and mortality, the same issues are also relevant to other clinical conditions including neonatal sepsis, febrile illness in children, pneumonia, and other respiratory tract infections with respect to the initiation, duration or change in antibiotic therapy. Again, the duration of antibiotic therapy is often undefined, and clinical features are of limited help in guiding discontinuation of therapy.1

Several serum biomarkers have been identified in recent years that have the potential to help diagnose local and systemic infections, differentiate bacterial and fungal infections from viral syndromes or noninfectious conditions, prognosticate, and ultimately guide management, particularly antibiotic therapy. Among these, procalcitonin is the most extensively studied biomarker.2, 3 Numerous studies have investigated the potential roles of procalcitonin in diagnosing and managing local and systemic infections.4-6 There is some evidence that procalcitonin is more specific for bacterial infections, with serum levels rising at the onset of infection and falling rapidly as the infection resolves compared with other markers.7, 8 However, its clinical utility in the diagnosis and management of patients with suspected infections remains unclear.

The objective of the Comparative Effectiveness Review (CER) on Procalcitonin-Guided Antibiotic Therapy9 prepared by the Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center (BCBSA TEC EPC) was to synthesize comparative studies examining the various uses of procalcitonin in the clinical management of patients with suspected local or systemic infection. The patient populations included those with suspected sepsis or other serious bacterial infections in critically ill adults, neonates with suspected early neonatal sepsis, patients with upper and lower respiratory tract infections, children with fever of unknown source, and postoperative patients with infection. Initial review of the literature during topic development and topic refinement suggested that the most common use for procalcitonin-guided management was in decision making related to the initiation or discontinuation of antibiotic therapy in these various populations. The major impetus of undertaking the CER was that a comprehensive review would determine the benefits and/or risks of procalcitonin-guided initiation and/or discontinuation of antibiotic therapy in different patient populations. In addition, this CER would also identify the major research needs related to procalcitonin-guided antibiotic therapy that require further prospective investigation and would serve as priorities for future research.

The following Key Question formed the basis for the CER:

In selected populations of patients with suspected local or systemic infection, what are the effects of using procalcitonin measurement plus clinical criteria for infection to guide initiation, discontinuation or a change of antibiotic therapy, when compared with clinical criteria for infection alone on:

- Intermediate outcomes, such as initiation, discontinuation or change of antibiotic therapy, antibiotic usage, and length of stay?
- Health outcomes, such as morbidity, mortality, function, quality of life, and adverse events of antibiotic therapy (persistent or recurrent infection, and antibiotic resistance)?

The CER results were reported separately by patient population because of different clinical characteristics and predicted outcomes. Conducting meta-analysis was precluded in most instances due to heterogeneity of outcome definitions, sparseness of commonly defined outcomes and lack of sufficient detail in outcome reporting. A meta-analysis was performed on short-term mortality (28-day or in-hospital mortality) in a group of five studies that included critically ill patients and those with ventilator-associated pneumonia. The pool of studies was too small to permit meaningful subgroup and sensitivity analyses. Additional meta-analyses were performed on antibiotic duration, ICU length of stay and hospital length of stay.

The findings from the draft CER revealed that procalcitonin guidance reduces antibiotic usage when used to discontinue antibiotics in adult ICU patients and to initiate or discontinue antibiotics in patients with respiratory tract infections, without increasing morbidity and mortality. In contrast, procalcitonin-guided intensification of antibiotics in adult ICU patients increases morbidity. There was also evidence that procalcitonin guidance reduces antibiotic usage for suspected early neonatal sepsis, but insufficient evidence on morbidity and mortality outcomes. Evidence was insufficient to draw conclusions on outcomes of procalcitonin guidance for: (1) fever of unknown source in children 1–36 months of age; or (2) preemptive antibiotics after surgery. The analytical framework that guided the draft CER is provided in Figure 1. Appendix A provides the draft findings from the CER report.

Figure 1 Analytic framework from draft CER for procalcitonin as a diagnostic indicator for infection and as an indicator of response to therapy

Note: AECOPD, acute exacerbations of chronic obstructive pulmonary disease.

Figure 1 is an analytic framework depicting the potential impact of using procalcitonin on both intermediate outcomes and health outcomes. Direct evidence of the impact of testing on health outcomes is shown by link A (morbidity, function, quality of life, and/or mortality) and links G and H (adverse events of testing/therapy). Indirect evidence would have to be assembled in the absence of randomized, controlled trials (RCTs) of the effects of testing on health outcomes. An early link in an indirect chain of evidence concerns the diagnostic accuracy of testing (B). Link C addresses whether test results influence decisions about therapy, which may have an impact on health outcomes (link D) or intermediate outcomes (link E)

### Evidence Gaps

Five evidence gaps related to specific populations or comparators were identified in the CER. They are as follows:

1. What are the outcomes of procalcitonin guidance in subgroups of patients who are immunocompromised?
2. What are the outcomes of procalcitonin guidance in pediatric patients?
3. What are the outcomes of procalcitonin guidance in identifying patients at risk of infection who might benefit from pre-emptive antibiotic therapy?
4. Does the use of procalcitonin guidance reduce antibiotic resistance and antibiotic adverse events?
5. How does procalcitonin-guided antibiotic therapy compare to other approaches to reducing unnecessary antibiotic use, such as antibiotic stewardship programs and implementation of practice guidelines?

Based on these evidence gaps, recommendations for future research targeted priority populations who were excluded explicitly from previous clinical trials or in whom insufficient evidence exists and who represent a high burden of illness. Immunocompromised patients with neutropenia or advanced HIV infection and transplant recipients would be important to study, as they often comprise a significant portion of the ICU population. Likewise, ambulatory care patients with mild to moderate immunosuppression on low-dose corticosteroids for chronic inflammatory conditions represent a significant portion of ambulatory care patients who may benefit from procalcitonin-guided antibiotic therapy instead of empiric coverage. The overuse of antibiotics in pediatric subpopulations (neonates; younger than 3 years of age; older than 3 years of age) is an understudied area in both inpatient and outpatient settings. Patients who are at higher risk of infection may benefit from pre-emptive antibiotic therapy given before any infection is clinically evident. These include patients undergoing elective colorectal surgery or other post-operative procedures, burn patients, and ICU patients.

The CER highlighted the importance of using appropriate study comparators and outcome measures that better reflect a real-world health care setting, thereby enhancing their applicability to clinical practice. So, although the CER did not assess the comparative effectiveness of using procalcitonin guidance versus antibiotic stewardship, this was noted as a recommendation for future research in recognition of the potential complementary role of procalcitonin to existing antibiotic stewardship programs and clinical practice guidelines for reducing antibiotic usage and associated adverse events in the acute care setting. Outcome measures should consider the consequences of reduction in antibiotic usage on antibiotic resistance, antibiotic-related adverse events, mortality and morbidity such as length of stay, local wound infection or sepsis.

The CER identified several common methodological weaknesses in the evidence base that should be addressed in future research. Consistent use of measures of total antibiotic exposure (e.g. mean days total exposure to all antibiotics per 1,000 days of followup) and of morbidity (e.g. need mechanical ventilation; severity of illness scores) would assist in comparing or pooling data across studies. Studies should provide an explicit rationale for noninferiority margins for mortality in specific patient populations, as the choice of a noninferiority margin incorporates clinical and statistical judgments. Transparent reporting and interpretation of nonsignificant differences should include clearly stating in the report if the study was powered to detect a difference in mortality or morbidity.