# Executive Summary

## Background

Sepsis is a serious condition with high morbidity and mortality for which clinical diagnostic criteria lack sensitivity and specificity. Early initiation of appropriate antibiotics and goal-directed therapies reduce mortality. Conversely, overuse and misuse of antibiotics, including continuing antibiotics longer than necessary for cure can result in adverse events and add to the increasing problem of antibiotic resistance.

Several serum biomarkers have been identified in recent years that have the potential to help diagnose local and systemic infections, differentiate bacterial and fungal infections from viral syndromes or noninfectious conditions, prognosticate, and ultimately guide management, particularly antibiotic therapy. Among these, procalcitonin is the most extensively studied biomarker. Numerous studies have investigated the potential roles of procalcitonin in diagnosing and managing local and systemic infections. However, its clinical utility in the diagnosis and management of patients with suspected infections remains unclear.

A Comparative Effectiveness Review (CER) was prepared by the Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center (BCBSA TEC EPC) on Procalcitonin-Guided Antibiotic Therapy.1 The objective of the CER was to synthesize comparative studies examining the various uses of procalcitonin in the clinical management of patients with suspected local or systemic infection. The patient populations included those with suspected sepsis or other serious bacterial infections in critically ill adults, neonates with suspected early neonatal sepsis, patients with upper and lower respiratory tract infections, children with fever of unknown source, and postoperative patients with infection.

The following Key Question formed the basis for the CER:

In selected populations of patients with suspected local or systemic infection, what are the effects of using procalcitonin measurement plus clinical criteria for infection to guide initiation, discontinuation, or a change of antibiotic therapy, when compared with clinical criteria for infection alone on:

- Intermediate outcomes, such as initiation, discontinuation or change of antibiotic therapy, antibiotic usage, and length of stay?
- Health outcomes, such as morbidity, mortality, function, quality of life, and adverse events of antibiotic therapy (persistent or recurrent infection, and antibiotic resistance)?

The analytical framework that guided the draft CER is provided in Figure A.

Figure A Analytic framework from draft CER for procalcitonin as a diagnostic indicator for infection and as an indicator of response to therapy

Note: AECOPD, acute exacerbations of chronic obstructive pulmonary disease; CER, Comparative Effectiveness Review.

Figure 1 is an analytic framework depicting the potential impact of using procalcitonin on both intermediate outcomes and health outcomes. Direct evidence of the impact of testing on health outcomes is shown by link A (morbidity, function, quality of life, and/or mortality) and links G and H (adverse events of testing/therapy). Indirect evidence would have to be assembled in the absence of randomized, controlled trials (RCTs) of the effects of testing on health outcomes. An early link in an indirect chain of evidence concerns the diagnostic accuracy of testing (B). Link C addresses whether test results influence decisions about therapy, which may have an impact on health outcomes (link D) or intermediate outcomes (link E)

Five evidence gaps related to specific populations or comparators were identified in the CER. The evidence gaps are as follows:

1. What are the outcomes of procalcitonin guidance in subgroups of patients who are immunocompromised?
2. What are the outcomes of procalcitonin guidance in pediatric patients?
3. What are the outcomes of procalcitonin guidance in identifying patients at risk of infection who might benefit from pre-emptive antibiotic therapy?
4. Does the use of procalcitonin guidance reduce antibiotic resistance and antibiotic adverse events?
5. How does procalcitonin-guided antibiotic therapy compare to other approaches to reducing unnecessary antibiotic use, such as antibiotic stewardship programs and implementation of practice guidelines?

Based on these evidence gaps, recommendations for future research targeted priority populations who were excluded explicitly from previous clinical trials or in whom insufficient evidence exists and who represent a high burden to the U.S. health care system (i.e., immunocompromised patients, ambulatory care patients, pediatric subgroups including neonates and young children, patients who are at higher risk of infection). The CER highlighted the importance of using appropriate study comparators and outcome measures that better reflect a real-world health care setting, thereby enhancing their applicability to clinical practice. Thus although the CER did not assess the comparative effectiveness of using procalcitonin guidance versus antibiotic stewardship, this was noted as a recommendation for future research recognizing the potential complementary role of procalcitonin to existing antibiotic stewardship programs and clinical practice guidelines for reducing antibiotic usage and associated adverse events in the acute care setting. Outcome measures should consider the consequences of reduction in antibiotic usage on antibiotic resistance, antibiotic-related adverse events, mortality and morbidity such as length of stay, local wound infection or sepsis. The CER also identified several common methodological weaknesses in the evidence base that should be addressed in future research (i.e., consistent use of measures of total antibiotic exposure and of morbidity, need for explicit rationale for noninferiority margins for mortality in specific patient populations, transparent reporting and interpretation of nonsignificant differences in outcome measures).

## Methods

To identify new research that might address the research needs in the CER, the project team updated literature searches from the CER and clinical trial searches using clinicaltrials.gov. Next, we convened a group of nine stakeholders (Stakeholder Panel or “Panel”), representing diverse perspectives, including methodological/research expertise, clinical experience, and consumer and payer representation. The Stakeholder Panel prioritized each research need and corresponding research questions using an online survey tool called SurveyMonkey^®^. The project team modified the Effective Health Care (EHC) Program Selection Criteria to be applicable to primary research rather than to systematic reviews of original research. The Panel used the modified selection criteria to prioritize both research needs and corresponding research questions. We compiled a final list, taking the Panel members' comments into consideration and paying particular attention to areas where ongoing efforts might overlap with prioritized research questions. The research questions were characterized using the PICOTS framework using the population(s), interventions, comparators, outcomes, timing, and settings. The project team then evaluated potential study designs to address each of the prioritized research questions in accordance with the recent Future Research Needs methods report authored by the EPCs for the Agency for Healthcare Research and Quality (AHRQ).2 The Panel provided insight into how future research agendas and proposed studies to address the research needs fit within these pre-specified criteria.

## Results

A total of 10 research needs were identified through a combination of the draft CER findings and discussions with the Stakeholder Panel. These research needs were grouped by specific patient groups addressed in the CER. Through an iterative process, the Panel prioritized the research needs; the EPC generated the final ranking of three research needs taking into account all Panel members' comments. These three research needs represented the priority populations the Panel determined were most in need of rigorous research, because the burden of illness is high and the information at present is insufficient or imprecise to permit conclusions about the use of procalcitonin for management of:

1. The critically ill patient (all ages) with suspected lower respiratory tract infection (LRTI) or general infection;
2. The patient (all ages) with suspected LRTI in the ambulatory care/emergency department setting in the United States;
3. The immunocompromised patient (all ages).

The Stakeholder Panel then generated and prioritized a list of potential research questions to address these three research needs. The final prioritized list of research needs and research questions accompanied by PICOTS elements are stated in Table A. Suggestions for future study designs are presented in Table B.

Table A Prioritized list of research needs and research questions with PICOTS information

Research Need | Research Question | Population(s) | Interventions | Comparators | Outcomes | Timing | Settings
The use of procalcitonin in the management of critically ill patients (all ages) with suspected lower respiratory tract infection (LRTI) or general infection Reason(s) for Research Need: For adults, insufficient evidence on health outcomes (e.g. antibiotic adverse events); Results from available studies are inconsistent (e.g. how adverse effects are defined, lack of details on types of adverse reactions) For pediatrics, insufficient or imprecise information given the limited number of studies | [underlined: 1.1] For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a PCT-guided strategy used to determine the duration of antimicrobial therapy safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT? [underlined: 1.2] For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a subsequent decrease in the serial PCT measurement indicate effective empiric treatment of the bacterial infection? [underlined: 1.3] For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT? | Critically ill adult or pediatric patient with suspected or proven pneumonia/sepsis | Clinical criteria with cultures if available plus PCT thresholds for determining presence/absence of bacterial infection | - Clinical criteria with cultures if available; - Institutional strategies for reducing antibiotic use (e.g. ASP, educational programs targeting staff in the outpatient setting) | - Hospital or ICU admission rate; - Hospital/ICU LOS; - Severity of illness; - ABT-associated adverse reactions (e.g. allergic reactions); - Emergence of drug resistant pathogens or superinfection; - Mortality (e.g. 30-day, hospital); - Antibiotic use (e.g. duration, days without ABT and total ABT exposure in children) | On admission or suspicion of infection, duration of followup (e.g. ≥ 30 days) | Hospital ICU
The use of procalcitonin in the management of patients (all ages) with suspected LRTI in the ambulatory care/emergency department setting in the U.S. Reason(s) for Research Need: For all ages, not the right information as results may not be applicable to U.S. setting; For pediatrics, insufficient or imprecise information given the lack of studies | [underlined: 2.1] For the otherwise healthy adult or pediatric patient who presents to ambulatory care/ED with fever and/or suspected acute LRTI, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT? | Adult or pediatric patient with no underlying medical conditions who presents with fever/suspected acute LRTI including community- acquired pneumonia, exacerbation of chronic obstructive pulmonary disease, and bronchitis | Clinical criteria with cultures if available plus PCT thresholds for determining presence/absence of bacterial infection | - Clinical criteria; - Strategies to reduce antibiotic use (e.g. CPGs, education) | - Hospital/ICU admission rate; - Hospital/ICU LOS; - Severity of illness; - ABT-associated adverse reactions (e.g. allergic reactions); - Emergence of drug resistant pathogens or superinfection; - Mortality (e.g. 30-day, hospital); - Days of restricted activity with PCT-guided therapy; - Relapse of infection; - Antibiotic use (e.g. duration, days without ABT and total ABT exposure in children) | On admission, duration of followup (e.g. ≥ 30 days) | - Ambulatory care; - Primary care clinic; - ED
The use of procalcitonin in the management of the immunocompromised patient (all ages) Reason(s) for Research Need: Insufficient or imprecise information given the limited number of studies; Patients with certain conditions were excluded from these studies, including neutropenia, transplant recipients (stem-cell or solid organ), and other patients on immunosuppressive therapy | [underlined: 3.1] For the immunocompromised patient who presents with suspected LRTI/sepsis, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT? [underlined: 3.2] For the immunocompromised patient with suspected LRTI/sepsis, does a PCT-guided strategy used to determine the duration of antibacterial therapy safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT? | Immunocompromised patients including patients infected with human immunodeficiency virus and with a CD4 count of < 200 cells/mm3, neutropenic patients, transplant recipients (stem-cell or solid organ), and other patients on immunosuppressive therapy | Clinical criteria with cultures if available plus PCT thresholds for determining presence/absence of bacterial infection | - Clinical criteria with cultures if available; - Institutional strategies for reducing antibiotic use (e.g. ASP, educational programs targeting staff the outpatient setting) | - Hospital or ICU admission rate; - Hospital/ICU LOS; - Severity of illness; - ABT-associated adverse reactions; - Emergence of drug resistant pathogens or superinfection; - Mortality (e.g. 30-day, hospital); - Days of restricted activity with PCT-guided therapy; - Relapse of infection; - Antibiotic use (e.g. duration, days without ABT and total ABT exposure in children) | On admission or suspicion of infection, duration of followup (e.g. ≥ 30 days) | - Outpatient/ED; - Hospital ward; - ICU

ABT = antibiotic therapy; ASP = antibiotic stewardship program; CPG = clinical practice guideline; ED = emergency department; ICU = intensive care unit; LOS = length of stay

Table B Study design considerations

Study Design Considerations | Randomized Controlled Trial | Controlled Before-After Study | Modeling
Description of design | Individuals randomly assigned to receive PCT-guided treatment strategy or standard care. Patients are followed during implementation for antibiotic use and health outcomes. Longer followup post implementation may be required if sustainability of outcome is desired (e.g., reduction of antibiotic use). Cluster RCTs that randomize at a hospital or ward level may be more suitable for population-level strategies when outcomes for individuals from a given unit are not independent. If pooling data across institutions is required, consensus on PCT cut-off points, standard care, outcome measures, minimum datasets and followup periods would be needed. | Antibiotic use and other health outcomes are compared in two or more groups of patients at the beginning and end of the study period. The study group receives the PCT-guided antibiotic treatment strategy part way into the study, and the control group receives standard care without use of PCT. Changes in outcomes from the beginning to the end of the study are compared across groups. Investigator controls timing of measurement(s) and variables measured, but not all intervention variables are in the control of the investigator. If pooling data across institutions is required, consensus on standard care, outcome measures, minimum datasets and followup periods would be needed. | Simulation model developed and validated to assess the value of individual strategies or individual components of comprehensive strategies across a range of populations, settings and conditions. Simulation models assume statistical association (e.g. between reduced antibiotic use and antibiotic-associated adverse events) and predict the consequences of the assumption (incidence of drug resistant pathogens). Agent based modeling (i.e., agent is the infectious bacteria) can be used to simulate the process of infectious disease transmission and be used to track drug resistance. This would allow for assessing the impact of a PCT-guided treatment strategy for reducing antibiotic use on rates of drug resistance over time.
Advantages of study design for producing a valid result | Best method to control for selection bias but potentially at the cost of generalizability. It should produce the most internally valid results. | Simple, efficient design with generalizable results. Design offers the ability to assess the temporal relationship between outcomes and ‘nonrandomizable’ events, e.g., if a hospital or unit has already adopted the use of PCT. Highly susceptible to confounding variables such as other concomitant antimicrobial therapy or dual viral/bacterial infection, regression to the mean and maturation effects. Internal validity may be strengthened by collecting data on confounding variables and matching study and control groups on pre-intervention outcomes of interest (e.g. antibiotic use, infection rates). Adding multiple pre-intervention observations is particularly important for evaluating temporal trends. Adequate statistical methods will be needed to control for confounders and secular trends in resistance and infection rates. | May be the best option to use when questions cannot be addressed using conventional clinical trial methods or existing data analysis, e.g. assessing the impact of various antibiotic treatment strategies on rates of drug resistance over the long term. May inform and help focus future clinical trials and data collection. Models can be tailored to multiple end users and perspectives, conditions and settings to enhance generalizability of findings and to help target interventions (different populations may call for different algorithms). Other forms of modeling (e.g. compartment based, decision tree, etc.) can be informative but will require more assumptions and thus greater variability with less confidence in the results. Its usefulness will be limited by available data and assumptions.
Resource use, size and duration | Depending on the strategy and desired effect size and outcome (e.g. the acceptability margins used to claim equivalence or noninferiority), costs, sample size and staff time needed for recruitment and implementation could be high. Recruitment of unit “clusters” willing to be randomized may constrain sample size. Duration likely to be a few weeks, which may keep costs down, but longer followup (several years) may be required to account for the lag between change in antibiotic use and rates of nosocomial drug resistance/super-infections. | Generally less resource intensive than an experimental design, but sample size will depend on desired effect and magnitude. Otherwise, size and duration issues would be similar to RCT. | May require substantial personnel time but is generally less resource intensive than primary studies. May require primary data collection to inform components of the model if reliable estimates cannot be obtained from the literature, empiric studies or experts.
Ethical, legal, and social issues | Perception of not receiving efficacious care can pose an ethical issue and barrier to recruitment if standards of clinical equipoise are not met. For cluster RCTs, a waiver of informed consent would be required. Legal mandates or clinical culture may impede randomization to new interventions or supersede trial objectives. | Perception of not receiving efficacious care can pose an ethical issue and barrier to recruitment if standards of clinical equipoise are not met. | Additional data collection may require institutional approvals or informed consent.
Availability of data or ability to recruit | Given the high mortality rates for sepsis, patient or their families may be reluctant to enroll in an RCT. Cluster RCTs require collaborative network of sites willing to participate. | Recruiting is feasible. Design may offer the best way to study interventions where randomization may be unacceptable to patients or providers. | Data would be obtained primarily from published sources, proprietary institutional databases, and expert opinion.

PCT = procalcitonin; RCT = randomized controlled trial.

## Discussion

This Future Research Needs project was developed from the BCBSA TEC EPC CER on Procalcitonin-Guided Antibiotic Therapy.1 A multidisciplinary Stakeholder Panel of nine participants used an 11-step process to identify and prioritize research needs and key research questions across the selected research needs. The final research questions reflect the deficiency in the evidence related to the key populations identified in the CER. Through this process, we propose a final list of three research needs and six associated research questions.

We used multiple techniques to engage stakeholders, including individual interviews, online surveys and conference calls. The literature search update allowed for more informed decisions in selecting topics that were not duplicative with current ongoing trials and to which further research would add the greatest value.

Future research concerns brought forth for consideration included addressing specific issues related to procalcitonin guidance in pediatrics and immunocompromised patients, as well as addressing both the duration and initiation of antibiotic therapy based on procalcitonin results in specific patient groups. Study design considerations included addressing the appropriate gold standard on which to evaluate the diagnostic properties of procalcitonin, the outcomes to consider for evaluations of procalcitonin, and factors that could influence procalcitonin test results.

One of the major challenges we encountered in our process was the various ways in which to combine/categorize many of the proposed topics; there was crossover and overlap between the various research needs and key underlying research questions across the top-ranked research needs. In addition, it was important to maintain the focus on the research needs in the evidence (and scope) addressed in the CER report. A limitation of this process was that the Stakeholder Panel was presented with the draft results of the CER; the conclusions did change between the draft and the final and thus the impact of these results on the rankings of the research needs is unknown.

## Conclusions

Three prioritized research needs and six research questions were identified in this process as important issues to take forward along with recommendations for future research. They are summarized in Table C and presented with the PICOTS framework in Table A.

Table C Summary of prioritized research needs and research questions

Research Need | Research Question
The use of procalcitonin in the management of critically ill patients (all ages) with suspected lower respiratory tract infection (LRTI) or general infection | [underlined: 1.1] For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a PCT-guided strategy used to determine the duration of antimicrobial therapy safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT? [underlined: 1.2] For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a subsequent decrease in the serial PCT measurement indicate effective empiric treatment of the bacterial infection? [underlined: 1.3] For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT?
The use of procalcitonin in the management of patients (all ages) with suspected LRTI in the ambulatory care/emergency department setting in the United States | [underlined: 2.1] For the otherwise healthy adult or pediatric patient who presents to ambulatory care/ED with fever and/or suspected acute LRTI, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT?
The use of procalcitonin in the management of the immunocompromised patient (all ages) | [underlined: 3.1] For the immunocompromised patient who presents with suspected LRTI/sepsis, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT? [underlined: 3.2] For the immunocompromised patient with suspected LRTI/sepsis, does a PCT-guided strategy used to determine the duration of antibacterial therapy safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT?

ED = emergency department; ICU = intensive care unit; LRTI = lower respiratory tract infection; PCT = procalcitonin.

The focus of the prioritized list of research questions is on the contribution of procalcitonin-guided clinical algorithms aimed at empirically treating suspected or confirmed bacterial infection in non-outbreak settings, including primary care, emergency/ambulatory care and intensive care. To that end, similar study designs may be used to address questions of the contribution of procalcitonin to the decision to initiate, maintain or discontinue antimicrobial therapy across a range of populations; in fact, a single study may sufficiently address all questions within a research need. Table B presents suggestions for the most valid and feasible study designs for future research of procalcitonin that could be considered for each of the prioritized research needs. The CER did not compare outcomes of using procalcitonin guidance versus antibiotic stewardship programs, nor did it address whether addition of procalcitonin to an antibiotic stewardship program improves outcomes. Therefore, a systematic review may be warranted to identify research needs from studies comparing procalcitonin-based strategies to institutional programs aimed at reducing antibiotic use before undertaking new primary research.

## References

1 Soni NJ, Samson DJ, Galaydick JL, et al. Procalcitonin-Guided Antibiotic Therapy. Comparative Effectiveness Review No. 78. (Prepared by the Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-2007-10058-I.) AHRQ Publication No. 12(13)-EHC124-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
2 Carey T, Sanders GD, Viswanathan M, Trikalinos TA, Kato E, Chang S. Framework for Considering Study Designs for Future Research Needs. Methods Future Research Needs Paper No. 8. (Prepared by the RTI–UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.