# Acknowledgments

The Research Team would like to acknowledge the following individuals for their contributions to this report: Claudia Bonnell, B.S.N., M.L.S., and Elaine Alligood, M.L.S., for literature searching and retrieval; Kathleen M. Ziegler, Pharm.D., for editorial input and assistance; Lisa Sarsany, M.A., for Government project management; Sharon Flaherty, M.A., for Government contracts support; Lisa Garofalo for administrative support; and David Samson, M.S., for his useful and comprehensive advice.

## Stakeholder Panel

The following individuals served as members of the Stakeholder Panel described in this report. Their contributions were invaluable. They were given the opportunity to review the report during the public comment period.

- Derek Angus, M.D., M.P.H.,
  University of Pittsburgh
  Pittsburgh, PA
- Carl Flatley, D.D.S., M.S.D.
  Sepsis Alliance
  Tampa, FL
- David Gilbert, M.D.
  Providence Portland Medical Center
  Portland, OR
- Inga Himelright, M.D., M.P.H., M.B.A.
  Blue Cross and Blue Shield of Tennessee
  Chattanooga, TN
- Alan Jones, M.D.
  University of Mississippi Medical Center
  Jackson, MS
- Stephen Kahn, Ph.D.
  Loyola University Medical Center
  Maywood, IL
- Joshua Metlay, M.D., Ph.D.
  University of Pennsylvania
  Philadelphia, PA
- Debra Palazzi, M.D.
  Texas Children's Hospital
  Houston, TX
- Hector Wong, M.D.
  Cincinnati Children's Hospital Medical Center
  Cincinnati, OH