# Discussion

Using the BCBSA TEC EPC CER on Procalcitonin-Guided Antibiotic Therapy,9 we developed an 11-step process for identifying and prioritizing clinically important research needs and research questions, with key input from a diverse group of stakeholders. The final research questions reflect the research needs in the evidence related to the key populations identified in the CER. Through this process, we propose a final list of three research needs and six associated research questions.

Several issues were brought forth for discussion by the Stakeholder Panel. First, Panel members emphasized that the overriding clinical issue in the U.S. is overuse of antibiotics. If the negative predictive value of procalcitonin can be determined to reliably identify patients who would not benefit from either initiating or continuing empiric antibiotic therapy, then procalcitonin may help reduce unnecessary antibiotic use and resistance, and improve health outcomes. Second, the Stakeholder Panel brought forth the need for further study on the ability of procalcitonin to detect bacterial translocation in the critical care setting (i.e., whether procalcitonin elevations are a surrogate marker for bacterial translocation). In patients with symptoms of sepsis but with no clear source of bacterial invasion, translocation may explain elevated procalcitonin levels which would support the need for antibiotic therapy. A further issue brought forth by the Stakeholder Panel was the need for targeted education strategies for health professionals regarding the appropriate use of procalcitonin given the increasing availability of the test; this issue would be important to consider when creating knowledge translation materials based on the research findings of the CER and this Future Research Needs initiative.

Finally, during discussions on potential study designs, the Stakeholder Panel brought forth issues that were not addressed in the CER but would be important to consider in future studies. Given the differences in procalcitonin assays and populations, it may be difficult to compare results across studies when different platforms or cut-off thresholds are used. There is a need to use consistent platforms and associated cut-off thresholds in order to compare results across studies, yet as the technology evolves, using a single platform might limit the generalizability of study results to other settings. At a minimum, the specific assay should be described. The Panel members acknowledged that this will be a challenging but fundamental issue to address in future research. Furthermore, the Panel members noted that there are newly developed antibodies for procalcitonin from a variety of companies that are not currently available for clinical use, but are used for research purposes. Health professionals may choose to use these technologies for convenience or cost purposes in clinical care. Thus, it would be beneficial if future trials are based on clinically-validated platforms in order to compare data that could be readily transferable to the bedside.

There are several strengths to our process. First, it is important that Panel members represented a wide range of relevant disciplines to ensure a balanced and broad perspective on research needs that addressed the research needs from the CER on this topic. Each stakeholder was highly interested and committed. There were high levels of participation at each step. Two Panel members were part of the Technical Expert Panel for the original CER, and one additional member acted as a peer reviewer. The consumer perspective was especially useful in drawing attention to ways in which patients experience care and the impact of sepsis on other aspects of their lives (e.g., work). The consumer representative noted significant practice variation across health care settings in the U.S. given the absence of rigorous clinical practice guidelines that incorporate procalcitonin; while outside the scope of the CER, there is a need to address effective prevention strategies for sepsis.

Second, given the breadth of potential topics, the introductory one-on-one calls with Panelists helped establish the preliminary list of research needs. This made the first conference call with the Stakeholder Panel more productive. Third, the literature search update allowed for more informed decisions in selecting topics that were not duplicative with current ongoing trials and to which further research would add the greatest value. Given the multiple populations under study, it was helpful to the project team to organize the literature search update and stakeholder information according to the research needs identified in the CER that evolved into specific research questions (e.g., initiating antimicrobial therapy, duration). These themes allowed the team to cover more comprehensively aspects of disease management along the continuum of care, care settings, and populations. The project team also sought feedback from the stakeholders to identify key published studies and ongoing trials across the list of research needs.

Finally, the internet surveys were successful in prioritizing issues across a broad range of categories. When provided with information on available research, rankings by the Stakeholder Panel appeared to be based on the amenability to comparative effectiveness research. A number of stakeholders were complimentary of our process. The Panel members agreed that the final list of research needs and research questions covered key topics for future study on this topic.

We encountered several challenges to our process. First, there were several ways to combine/categorize many of the proposed topics. There was crossover and overlap between the various research needs, and the key underlying research questions across the top-ranked three research needs. The categorization was dependent on how the Stakeholder Panel wanted to approach different topic areas. For example, the proposed topics could be categorized either by different segments of the population (adult, pediatric), specific settings (e.g., ICU, urgent care/ED), or different uses of procalcitonin (initiation of antibiotic therapy, duration) in various populations. Second, the Stakeholder Panel noted that studies of diagnostic performance and interventional studies were at different stages in different populations. For example, there have been many studies in target populations of adults presenting with suspected LRTI, and thus future clinical trials could progress toward interventional studies; once the benefits and harms of the test have been established, studies could then evaluate dissemination strategies, and availability and physician acceptance of the test. For other populations, such as in immunocompromised patients or children, data on procalcitonin diagnostic performance may be inadequate at present. The conceptual framework of evaluating the efficacy of procalcitonin (Figure 3) was useful in guiding these discussions with the Stakeholder Panel.

Third, it was important to maintain the focus on the research needs in the evidence (and scope) addressed in the original CER. The research needs were grouped by categories that could be linked to the CER scope, as the team had the evidence reviews and the updated literature search to back the findings. This always presents a challenge as evidenced by some of the topics brought forth by the Stakeholder Panel listed in the previous paragraphs (differences between assays, bacterial translocation, physician education, etc.). The project team reiterated during the teleconference calls with the Stakeholder Panel the focus of the CER and this Future Research Needs initiative; any additional issues of concern and importance raised by the Panel members would be addressed in the discussion section of the report submitted to AHRQ. Finally, one additional challenge or a limitation of this process was that the Stakeholder Panel was presented with the draft results of the CER; the conclusions did change between the draft and the final report and thus the impact of these results on the rankings of the research needs is unknown.