# Conclusion

This Future Research Needs project was developed using the findings of the BCBSA TEC EPC CER. We engaged a multidisciplinary Stakeholder Panel of nine participants using an 11-step process to identify and prioritize research needs and key research questions across the selected research needs. The results of this process are the three prioritized research needs and six research questions in Table 6.

Table 6 Prioritized research needs and research questions

Research Need | Research Question
The use of procalcitonin in the management of critically ill patients (all ages) with suspected LRTI or general infection | [underlined: 1.1] For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a PCT-guided strategy used to determine the duration of antimicrobial therapy safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT? [underlined: 1.2] For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a subsequent decrease in the serial PCT measurement indicate effective empiric treatment of the bacterial infection? [underlined: 1.3] For the critically ill/ICU adult or pediatric patient with suspected pneumonia/sepsis, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT?
The use of procalcitonin in the management of patients (all ages) with suspected LRTI in the ambulatory care/emergency department setting in the U.S. | [underlined: 2.1] For the otherwise healthy adult or pediatric patient who presents to ambulatory care/ED with fever and/or suspected acute LRTI, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT?
The use of procalcitonin in the management of the immunocompromised patient (all ages) | [underlined: 3.1] For the immunocompromised patient who presents with suspected LRTI/sepsis, does a strategy for initiating (and maintaining) antimicrobial therapy based on PCT safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT? [underlined: 3.2] For the immunocompromised patient with suspected LRTI/sepsis, does a PCT-guided strategy used to determine the duration of antibacterial therapy safely reduce antibiotic use and improve health outcomes compared with a strategy not based on PCT?

ED = emergency department; ICU = intensive care unit; LRTI = lower respiratory tract infection; PCT = procalcitonin