# Survey Results of Research Questions

Rank | Research Questions | Total Votes^i^ | Weighted Score
1 | For ICU patients with pneumonia/sepsis, does a PCT-guided strategy used to determine the duration of antibacterial therapy improve health outcomes compared to a strategy not based on PCT? | 8 | 27
2 | For the low risk (otherwise healthy) patient who presents to urgent care/ER with fever and suspected acute LRTI, can the serum PCT level distinguish bacterial from non-bacterial infection and improve health outcomes? | 5 | 17
2 | For ICU patients with a high uncertainty of pneumonia/sepsis, does a strategy for initiating antimicrobial therapy based on PCT improve health outcomes compared to a strategy not based on PCT? | 5 | 17
4 | For ICU patients with pneumonia/sepsis, following initiation of empiric antibacterial therapy, does a subsequent decrease in the PCT serum concentration indicate effective treatment of the bacterial infection? | 4 | 12
5 | For the immunocompromised patient who presents with suspected LRTI/sepsis, does a strategy for initiating antimicrobial therapy based on PCT improve health outcomes compared to a strategy not based on PCT? | 4 | 10
6 | For the immunocompromised patient who presents with suspected LRTI/sepsis, is PCT a reliable early indicator of bacterial infection? | 3 | 11
7 | For patients with underlying stable chronic disease (e.g. diabetes, renal disease, but excluding immunocompromised patients) and a high uncertainty of infection, is PCT a reliable indicator of bacterial infection? | 3 | 9
8 | For the high risk pediatric patient who presents with fever, is PCT a reliable indicator of early infection/sepsis? | 3 | 8
8 | For the immunocompromised patient with suspected LRTI/sepsis, can the duration of therapy be safely based on normalization of the serum PCT level? | 3 | 8
10 | For patients with chronic lung disease who present to urgent care/ER with suspected acute LRTI, can the serum PCT level distinguish bacterial from non-bacterial infection and improve health outcomes? | 2 | 6
11 | For critically ill hypotensive patients with no clear focal bacterial infection and negative blood cultures, does an elevated PCT level indicate occult translocation of intestinal bacteria into the bowel wall, portal vein, and/or bloodstream? | 2 | 5
12 | For the high risk pediatric patient who presents with fever and suspected early sepsis, does a strategy for initiating antimicrobial therapy based on PCT improve health outcomes compared to a strategy not based on PCT? | 2 | 4
13 | In the pediatric patient with suspected sepsis but an otherwise negative culture, can the duration of therapy be safely based on normalization of the serum PCT level? | 1 | 1

Note: ER, emergency room; ICU, intensive care unit; LRTI, lower respiratory tract infection; PCT, procalcitonin.

i Responses from nine (of nine) panel members.