# Survey Results of Research Needs

Research Needs and Preliminary Research Questions | Total Votes^*^ | Weighed Total | Technical Efficacy (Level 1)^**^ | Diagnostic Performance (Levels 2 & 3) | | Impact on Treatment (Level 4) | Impact on Patient Outcomes (Level 5) | Societal Impact (Level 6)
1. Management of critically ill patients (all ages) with suspected lower respiratory tract infection (LRTI) or general infection | 8 | 33
1.1.1. Is PCT a valid indicator of bacterial infection in ‘non-septic’ patients with suspected LRTI or general infection? | | | | ✓ | ✓
1.1.2. What is the comparative effectiveness of clinical criteria with vs. without PCT for discontinuing/ changing antibiotic therapy in ‘non-septic’ persons with suspected LRTI or general infection? | | | | | | ✓ | ✓ | ✓
1.2.1. Is PCT a valid indicator of bacterial infection in patients hospitalized with a non-infectious condition who develop delayed fever without signs of sepsis? | | | | ✓ | ✓
1.2.2. What is the comparative effectiveness of clinical criteria with vs. without PCT for initiating antibiotic therapy in persons hospitalized with a non-infectious condition who develop delayed fever without signs of sepsis? | | | | | | ✓ | ✓ | ✓
2. Management of patients (all ages) with suspected LRTI in the emergency room setting in the U.S. | 8 | 31
2.1. Is PCT a valid indicator of bacterial infection in patients who present to the emergency room with suspected LRTI? | | | | ✓ | ✓
2.2. What is the comparative effectiveness of clinical criteria with PCT vs. without PCT for initiating antibiotic therapy in patients with suspected LRTI? | | | | | | ✓ | ✓ | ✓
3. Management of adults with chronic diseases presenting with suspected pneumonia/sepsis | 7 | 22
3.1. For adults with chronic disease with suspected pneumonia/sepsis, is PCT a valid indicator of bacterial infection? | | | | ✓ | ✓
3.2. For adults with chronic disease with suspected pneumonia/sepsis, what is the comparative effectiveness of clinical criteria with PCT vs. without PCT for initiating antibiotic therapy? | | | | | | ✓ | ✓ | ✓
3.3. For adults with chronic disease with suspected pneumonia/sepsis, what is the comparative effectiveness of clinical criteria with PCT vs. without PCT for discontinuing/changing antibiotic therapy? | | | | | | ✓ | ✓ | ✓
4. Management of the high risk pediatric patient (neonate, age 3-36 months) [with suspected early sepsis] to rule out need for antibiotics | 7 | 13
4.1. For high risk pediatric patients who present with suspected early sepsis, is PCT a valid indicator of bacterial infection? | | | | ✓ | ✓
4.2. For high risk pediatric patients who present with suspected early sepsis, what is the comparative effectiveness of clinical criteria with PCT vs. without PCT for initiating antibiotic therapy? | | | | | | ✓ | ✓ | ✓
5. Management of the immunocompromised patient (all ages) | 6 | 14
5.1.1. For patients with mild to moderate immunosuppression, is PCT a valid indicator of bacterial infection? | | | | ✓ | ✓
5.1.2. For patients with mild to moderate immunosuppression, what is the comparative effectiveness of clinical criteria with PCT vs. without PCT for initiating antibiotic therapy? | | | | | | ✓ | ✓ | ✓
5.1.3. For patients with mild to moderate immunosuppression, what is the comparative effectiveness of clinical criteria with PCT vs. without PCT for discontinuing/changing antibiotic therapy? | | | | | | ✓ | ✓ | ✓
5.2.1. For patients with severe immunosuppression, is PCT a valid indicator of bacterial infection? | | | | ✓ | ✓
5.2.2. For patients with severe immunosuppression, what is the comparative effectiveness of clinical criteria with PCT vs. without PCT for initiating antibiotic therapy? | | | | | | ✓ | ✓ | ✓
5.2.3. For patients with severe immunosuppression, what is the comparative effectiveness of clinical criteria with PCT vs. without PCT for discontinuing/changing antibiotic therapy? | | | | | | ✓ | ✓ | ✓
6. Management of patients (all ages, including post-op) with fever of unknown source | 5 | 13
6.1. For patients who present with a fever of unknown source, is PCT a valid indicator of bacterial infection? | | | | ✓ | ✓
6.2. For patients who present with a fever of unknown source, what is the comparative effectiveness of clinical criteria with PCT vs. without PCT for initiating antibiotic therapy? | | | | | | ✓ | ✓ | ✓
7. Management of the pediatric patient with chronic illness presenting with suspected bacterial pneumonia (e.g., in cystic fibrosis, sickle cell disease) | 3 | 7
7.1. For pediatric patients with chronic illness, is PCT a valid indicator of bacterial infection? | | | | ✓ | ✓
7.2. For pediatric patients with chronic illness who present with suspected bacterial infection, what is the comparative effectiveness of clinical criteria with PCT vs. without PCT for initiating antibiotic therapy? | | | | | | ✓ | ✓ | ✓
7.3. For pediatric patients with chronic illness who present with suspected bacterial infection, what is the comparative effectiveness of clinical criteria with PCT vs. without PCT for discontinuing/changing antibiotic therapy? | | | | | | ✓ | ✓ | ✓
8. Management of patients (all ages) on immune-modulators (e.g., steroids) and other systemic therapies [This question could be considered as subset of # 5 on the immunocompromised patient] | 1 | 2
9. Management of the pediatric patient with suspected bone/joint infections | 0 | 0
10. Management of the pediatric patient with periodic fever syndrome | 0 | 0

Note: PCT,procalcitonin.

* Responses from nine (of nine) panel members

** Assumption: This column on Technical efficacy (Level 1) is shaded to indicate that technical feasibility of test has been determined.

Checkmark (✓) indicates information needed to address research question