# List of Research Needs

Research Needs | Systematic Review Results | Stakeholders | Primary Studies/Reviews | Ongoing Clinical Trials
What are the outcomes of PCT guidance in subgroups of patients who are immunocompromised? | - Little evidence available because often excluded from trials.; - Represent significant ICU subpopulations and other conditions e.g. CF, pregnancy.; - Vulnerable to antibiotic resistance and adverse effects of antibiotics.; - Host cytokine response affects PCT levels, so PCT cut-offs may differ in these populations.; - Potential role for PCT guidance in reducing antibiotic usage in the ambulatory patients with mild to moderate immunosuppression vs. standard therapy. | - This is a major priority population.; - Depends on definition of immunocompromised. PCT expression of genes that control PCT are mediated by innate immunity, not adaptive immunity. (e.g., patients with febrile neutropenia seem to respond similar to non-immunocompromised.) | None identified | None identified
What are the outcomes of PCT guidance in pediatric patients? | - Evidence is limited to two underpowered studies of children ages 1-36 months in the acute care hospital setting.; - No evidence for children ages 3 years to 18 years.; - Future studies of PCT-guided initiation and discontinuation of antibiotics will be extremely important to address the overuse of antibiotics in both the inpatient and outpatient settings. | - This is a major priority population.; - Specifically, how should PCT be used in the febrile infant who presents through the ER?; - Many early (albeit) observational studies of PCT were in pediatrics.; - In pediatric patients age 3-36 months use PCT to rule out antibiotics.; - Specific populations in need of study of PCT-guided antibiotic therapy are; ○ Critical care patients; ○ Severely immunocompromised patients (e.g., leukemia or febrile neutropenia).; ○ Patients who present with fever without a source, especially 1-3 months of age (even up to 3 years).; ○ Periodic fever syndromes.; ○ Suspected bacterial pneumonia (e.g., in cystic fibrosis).; ○ Children with bone and joint infections (in whom inflammatory markers are used to differentiate inflammation from infection). | 1. Esposito S, et al. Procalcitonin measurements for guiding antibiotic treatment in pediatric pneumonia. Respir Med 2011 Dec;105(12): 1939-45. PMID: 21959024.; 2. Jordan I, et al. Procalcitonin: A useful biomarker to discriminate infection after cardiopulmonary bypass in children. Pediatr Crit Care Med 2012 Mar 14. PMID: 22422165.; 3. Phillips RS, et al. Systematic review and meta-analysis of the value of initial biomarkers in predicting adverse outcome in febrile neutropenic episodes in children and young people with cancer. BMC Med 2012 Jan 18;10(1): 6. PMID: 22257704.; 4. Unal S, et al. Procalcitonin is more useful than C-reactive protein in differentiation of fever in patients with sickle cell disease. Journal of pediatric hematology/oncology 2012 Mar;34(2):85-9. PMID: 22367384.; 5. Yuksel S, et al. The value of procalcitonin measurements in children with familial Mediterranean fever. Rheumatology international 2011 Nov 6. PMID: 22057145; 6. Louw JJ, et al. Serum procalcitonin is not an early marker of pulmonary exacerbation in children with cystic fibrosis. European journal of pediatrics 2012 Jan;171(1):139-42. PMID: 21630003. | NCT Number: NCT00854932 Title: Neonatal Procalcitonin Intervention Study Completion date: July 2013 URL: ClinicalTrials.gov/show/NCT00854932
What are the outcomes of PCT guidance in identifying patients at risk of infection who might benefit from pre-emptive antibiotic therapy? | - Limited evidence from one small study in preoperative patients scheduled for colorectal surgery suggests that PCT may identify a high risk group who would benefit from preemptive antibiotic therapy.; - Larger studies are needed to confirm results e.g. reduce infectious complications.; - Other high risk patient populations include burns, ICU residents, and other postoperative patients | - How to use PCT in the febrile hospital patient (e.g., post trauma or post surgery). The existing research has studied heterogeneous populations. We need to determine cut-offs for these specific populations.; - Post-op patients to reduce risk of bacterial translocation from the GI tract. This is just ripe for clinical study because we have two markers that can be correlated for supporting evidence of bacterial translocation. Both are easily available and are generally accepted in critical care medicine. | Jordan I, et al. Procalcitonin: A useful biomarker to discriminate infection after cardiopulmonary bypass in children. Pediatr Crit Care Med 2012 Mar 14. PMID: 22422165. | NCT Number: NCT01264549 Title: Stroke Adverse Outcome is Associated With Nosocomial Infections: PCTus- Guided Antibacterial Therapy in Severe Ischemic Stroke Patients (STRAWINSKI) Completion Date: July 2012 URL: ClinicalTrials.gov/show/NCT01264549
Does the use of PCT guidance reduce antibiotic resistance and antibiotic adverse events? | - Evidence from RCTs was insufficient to show a correlation between an observed reduction in antibiotic use and effect of antibiotic adverse reactions, super-infections, or drug resistance.; - Studies lacked standardized reporting of adverse events from antibiotics, especially the incidence of C. difficile and active surveillance for colonization with drug-resistant pathogens. | - Need standardized reporting of outcomes | 1. Albrich WC, et al. Procalcitonin-guided antibiotic stewardship in lower respiratory tract infections. A real-life international multicentre quality surveillance (ProREAL). Clinical Microbiology and Infection 2011;17:S9 [ESCMID]; 2. Li H, et al. Meta-analysis and systematic review of procalcitonin-guided therapy in respiratory tract infections. Antimicrob Agents Chemother 2011 Dec;55(12):5900-6. PMID: 21947386.; 3. Esposito S, et al. Procalcitonin measurements for guiding antibiotic treatment in pediatric pneumonia. Respir Med 2011 Dec;105(12): 1939-45. PMID: 21959024.; 4. Jensen JU, et al. Kidney failure related to broad-spectrum antibiotics in critically ill patients: secondary end point results from a 1200 patient randomised trial. BMJ open 2012;2(2):e000635. PMID: 22411933 | NCT01494675 Title: Procalcitonin as a Tool to Shorten Antibiotic Therapy in the ICU Completion Date: Dec 2011 URL: ClinicalTrials.gov/show/NCT01494675 NCT00832039 Title: Placebo Controlled Trial of Sodium Selenite and Procalcitonin Guided Antimicrobial Therapy in Severe Sepsis Completion date: Nov 2013 URL: ClinicalTrials.gov/show/NCT00832039 NCT01018199 Title: Procalcitonin Versus C-reactive Protein to Guide Therapy in Community Acquired Pneumonia Completion Date: August 2014 URL: ClinicalTrials.gov/show/NCT01018199 NCT01264549 Title: Stroke Adverse Outcome is Associated With Nosocomial Infections: PCTus- Guided Antibacterial Therapy in Severe Ischemic Stroke Patients (STRAWINSKI) Completion Date: July 2012 URL: ClinicalTrials.gov/show/NCT01264549
How does PCT-guided antibiotic therapy compare to other approaches to reducing unnecessary antibiotic use, such as antibiotic stewardship programs and implementation of practice guidelines? | - Primary studies and systematic reviews are needed to compare the effects of a broad range interventions (with or without PCT) on the overuse of antibiotics and clinical outcomes; - Studies are needed to address four important methodologic weaknesses that were common across the studies and bodies of evidence reviewed in this report. | - A major priority is impact of antibiotic stewardship programs vs. alternatives e.g., PCT-guided antibiotic therapy or clinical practice guideline (CPG)-guided antibiotic therapy, the latter being a systematic review the societies presented to AHRQ a few years ago.; - Important area for further study. | 1. Li H, et al. Meta-analysis and systematic review of procalcitonin-guided therapy in respiratory tract infections. Antimicrob Agents Chemother 2011 Dec;55(12):5900-6. PMID: 21947386; 2. Esposito S, et al. Procalcitonin measurements for guiding antibiotic treatment in pediatric pneumonia. Respir Med 2011 Dec;105(12):1939-45. PMID: 21959024 | NCT01379547 Title: Procalcitonin to Shorten Antibiotics Duration in ICU Patients Completion Date: Dec 2012 URL: ClinicalTrials.gov/show/NCT01379547 NCT00832039 Title: Placebo Controlled Trial of Sodium Selenite and Procalcitonin Guided Antimicrobial Therapy in Severe Sepsis Completion Date: Nov 2013 URL: ClinicalTrials.gov/show/NCT00832039

Other priority populations/questions | Stakeholders | References
Is PCT a valid indicator of source control? | - Jensen study used different endpoints and recommendations of continuing/increasing antibiotics if PCT not decreased; both differ from U.S. practice. | Gilbert DN. Use of plasma procalcitonin levels as an adjunct to clinical microbiology. Journal of clinical microbiology 2010 Jul;48(7):2325-9. PMID: 20421436.
How long should we treat the infection? | - In U.S., PCT measured every 2-4 days depending on diagnosis until ∼.12, which is typically 1-2 days shorter than recommended. How long should we treat the bacteremia, pneumonia, etc. The literature has these very arbitrary re durations of treatment. | Gilbert DN. Use of plasma procalcitonin levels as an adjunct to clinical microbiology. Journal of clinical microbiology 2010 Jul;48(7):2325-9. PMID: 20421436.
Patients admitted to the ED with a lower RTI in the U.S.. | - #1 priority population. This population represents a high burden of illness, but all randomized evidence is solely from European trials, which have shown PCT useful for reducing antibiotic use in this population without reducing outcomes. This has not been studied in U.S. EDs where differences in medical culture, regulation and practice exist. Can these benefits be realized in the U.S. where clinicians may or may not respond to a prompt to obtain PCT levels or obtain them prior to antibiotic prescription? | Gilbert DN. Procalcitonin as a biomarker in respiratory tract infection. Clin Infect Dis 2011 May;52 Suppl 4:S346-50. PMID: 21460294.
Patients with chronic disease e.g. chronic inflammatory lung disease, CHF, metabolic syndromes | - These patients make up the bulk of patients we see with suspected pneumonia or sepsis and increasingly the burden of health delivery of patients who are see in ambulatory and urgent care settings. | [Horie (sp?), 2011 or 2012 in North American Journal of Medical Sciences (not currently indexed in PubMed)]
Patients on immunomodulators (e.g., steroids) and other systemic therapies. | - How do these therapies impact PCT measurement used for treatment planning? | Gilbert DN. Use of plasma procalcitonin levels as an adjunct to clinical microbiology. Journal of clinical microbiology 2010 Jul;48(7):2325-9. PMID: 20421436.
Unexplained PCT elevation e.g. bacterial translocation from the GI tract. | - This is just ‘ripe’ for clinical study because we have two markers that can be correlated for supporting evidence of bacterial translocation. Both are easily available and are generally accepted in the critical care medicine world. | Gilbert DN. Use of plasma procalcitonin levels as an adjunct to clinical microbiology. Journal of clinical microbiology 2010 Jul;48(7):2325-9. PMID: 20421436.
Fever of unknown origin | - Patients with central venous line or other invasive devices who present with fever with an unknown source.; - PCT may help identify etiology. | Gilbert DN. Use of plasma procalcitonin levels as an adjunct to clinical microbiology. Journal of clinical microbiology 2010 Jul;48(7):2325-9. PMID: 20421436.
Dual infection | - PCT levels used to determine viral from bacterial, but need etiology. Need basic science and clinical studies to give physicians more confidence as far as predicting whether a bacterial vs. viral infection is present (help with antibiotic stewardship).

Other issues identified by Stakeholders
Methodological | - RCTs are not testing the biomarker, but rather the success of the treatment strategy with versus without PCT. Many systematic reviews have not addressed this point. RCTs should incorporate PCT derived from newer high sensitive assays. The older assays have not been successful as a rule-out test. Systematic reviews often do not address this point.; - Need to study the effect of PCT on empiric antibiotic therapy. Most evidence is from Europe, not correlated with etiology. Needs to be confirmed in prospective trials.; - For PCT to be useful, need results within 1 hour of specimen collection, but most literature has measured it within 24 hours. A laboratory perspective is essential in planning studies.
General | - Major priority issue - Use of PCT is variable because there are no guidelines for using it in practice in U.S.; - Overall, need studies that give physicians more confidence in PCT values e.g., viral vs. bacterial, source control, guiding duration of therapy.; - Agree with the Research Needs. There have been few RCTs in these areas, the most recent being a Scandinavian trial that found PCT not useful as a rule in test for antibiotic use. Not sure if this trials has yet been published.; - Strongest evidence for PCT is in fairly low-risk patients with RTIs. How generalizable are its diagnostic characteristics to other patient populations?; - CDC is funding a study of an assay for screening a number of biomarkers, including PCT, for informing the duration of antibiotic treatment for sepsis in the ICU in adults and children. Just started.; - Need study of the use of multi-panel assays to differentiate bacterial from viral or fungal infections.