# Search Strategy for Ongoing Studies

PubMed Search Strategy
1. procalcitonin[tiab] OR procalcitonin[title] OR PCT[tiab] = 2037
2. 1 AND (“last 60 days”[PDat]) = 65 English = 60 Added to EndNote = 36

EMBASE Search Strategy
1. PCT OR ‘procalcitonin’/de OR procalcitonin AND [20-3-2012]/sd NOT [22-4-2012]/sd AND [english]/lim AND [2012-2012]/py = 69
2. Limited to Publication Types: Articles OR in Press OR Conf Abstract OR Review = 52 Added to EndNote

Clinical Trials.Gov
1. Procalcitonin [ALL-FIELDS] OR PCT [ALL-FIELDS] AND First Received: 3/20/2012 to 4/22/2012
2. Procalcitonin [ALL-FIELDS] OR PCT [ALL-FIELDS] AND Last Updated: 3/20/2012 to 4/22/2012
3. 1 OR 2 = 8 Added to EndNote

Cochrane Search Strategy
1. Procalcitoni :ti, ab,kw OR PCT:ti,ab,kw = 291
2. 1 AND 2012-2012 = 1 already in EndNote