# Summary of Evidence From Draft Comparative Effectiveness Review

Patient Group | Outcome | Unit | No. of Studies | Reference | No. of Subjects | B | C | D | P | Overall Grade | Effect^*^
Critically ill/VAP patients (antibiotic discontinuation) | Antibiotic usage | Duration of use, days | 5 | 14-18 | 938 | L | Y | Y | Y | High | Improve ( Range: -1.7 to − 5)
Critically ill/VAP patients (antibiotic discontinuation) | Mortality | In-hospital, overall or 28- day | 5 | 14-18 | 938 | L | Y | Y | Y | Moderate | No worse
Critically ill/VAP patients (antibiotic discontinuation) | Morbidity | ICU length of stay, days | 5 | 14-18 | 837 | L | Y | Y | Y | Moderate | No worse
Critically ill/VAP patients (antibiotic intensification) | Morbidity | Percent days in ICU with GFR<60 | 1 | 21 | 1200 | L | U | Y | Y | Moderate | Worse (5.0%, 95% CI: 3.0, 6.9 )
Critically ill/VAP patients (antibiotic intensification) | Morbidity | Percent days on ventilator | 1 | 21 | 1200 | L | U | Y | Y | Moderate | Worse (4.9%, 95%CI: 3.0, 6.7)
Respiratory tract infection | Antibiotic usage | Duration of use, days | 7 | 23-27,29-30 | 3284 | L | Y | Y | Y | High | Improve (Range:-1 to -7)
Respiratory tract infection | Antibiotic usage | Prescription Rate | 7 | 23-30 | 3492 | L | Y | Y | Y | High | Improve (Range:-2 to -7%)
Respiratory tract infection | Mortality | ≤ 6 wks or 6 months | 8 (7/1) | 23-30 | 3492 | L | Y | Y | Y | Moderate | No worse
Respiratory tract infection | Morbidity | Hospital length of stay | 5 | 25-26, 28-30 | 2303 | M | Y | Y | Y | Moderate | No worse
Respiratory tract infection | Morbidity | ICU admission rates | 5 | 25-26, 28-30 | 2303 | M | Y | Y | Y | Moderate | No worse
Respiratory tract infection | Morbidity | Antibiotic Adverse Events | 3 | 24, 25, 27 | 2367 | L | N | Y | N | Insufficient | Unknown
Neonatal sepsis | Duration of antibiotic use | Hours | 1 | 31 | 121 | L | U | Y | Y | Moderate | Improve (-22.4, p=0.012)
Neonatal sepsis | Morbidity | Recurrence of infection | 1 | 31 | 121 | L | U | Y | N | Insufficient | Unknown
Neonatal sepsis | Mortality | In-hospital | 1 | 31 | 121 | L | U | Y | N | Insufficient | Unknown
Fever of unknown source in children | Antibiotic use | Prescription rate | 1 | 32 | 384 | H | U | Y | N | Insufficient | Unknown
Fever of unknown source in children | Morbidity | Hospitalization rate | 1 | 32 | 384 | H | U | Y | N | Insufficient | Unknown
Fever of unknown source in children | Mortality | In-hospital | 1 | 32 | 384 | H | U | Y | N | Insufficient | Unknown
Preemptive Postoperative Antibiotic Therapy | Morbidity | Sepsis/SIRS | 1 | 33 | 20 | U | U | Y | N | Insufficient | Unknown
Preemptive Postoperative Antibiotic Therapy | Mortality | In-hospital | 1 | 33 | 20 | U | U | Y | N | Insufficient | Unknown

Note: This table lists the findings from the draft CER report; the conclusions have changed between the draft and the final report.

B, risk of bias; C, consistency; CI, confidence interval; D, directness; GFR, Glomerular filtration rate; ICU, intensive care unit; N/A, not applicable; N, No; P, Precision; SIRS, systemic inflammatory response syndrome; U, unknown; VAP, ventilator associated pneumonia; Y,yes.

* Comparison between procalcitonin measurement plus clinical criteria versus clinical criteria alone to guide to guide initiation, discontinuation or a change of antibiotic therapy.