# Acronyms and Abbreviations

ABT: Antibiotic therapy
AHRQ: Agency for Healthcare Research and Quality
ASP: Antibiotic stewardship program
BCBSA TEC: Blue Cross and Blue Shield Association Technology Evaluation Center
CER: Comparative Effectiveness Review
CPG: Clinical practice guideline
EHC: Effective Health Care
EPC: Evidence-based Practice Center
ED: Emergency department
ICU: Intensive care unit
LOS: Length of stay
LRTI: Lower respiratory tract infection
PICOTS: Population(s), Interventions, Comparators, Outcomes, Timing, Settings
RCT: Randomized controlled trial
RTI-UNC: Research Triangle Institute International-University of North Carolina