# References

1 Armstrong GL, Wasley A, Simard EP, et al. The prevalence of hepatitis C virus infection in the United States, 1999 through 2002. Ann Intern Med. 2006;144:705-14. [pmid: 16702586].
2 Ly KN, Xing J, Klevens RM, et al. The increasing burden of mortality from viral hepatitis in the United States between 1999 and 2007. Ann Intern Med. 2012;156(4):271-8. [pmid: 22351712].
3 Kim WR. Motion - the available treatments for hepatitis C are cost effective: arguments against the motion. Can J Gastroenterol. Oct. 2002;16(10):710-5. [pmid: 12420033].
4 Davis GL, Alter MJ, El-Serag H, et al. Aging of hepatitis C virus (HCV)-infected persons in the United States: a multiple cohort model of HCV prevalence and disease progression. Gastroenterol. Feb. 2010;138(2):513-21. [pmid: 19861128].
5 National Center for HIV/AIDS VH, STD & TB Prevention. Disease Burden from Viral Hepatitis A, B, and C in the United States. Centers for Disease Control. 2011. www.cdc.gov/hepatitis/hcv/StatisticsHCV.htm. Accessed June 1 2012.
6 Swain M, Lai MY, Shiffman ML, et al. Durability of sustained virological response (SVR) after treatment with peginterferon alfa-2A (40KD) (PEGASYS) alone or in combination with ribavirin (COPEGUS): results of an ongoing long-term follow-up study. Hepatology. 2004;40(4 Suppl 1):400A-1A.
7 Swain MG, Lai MY, Shiffman ML, et al. A sustained virologic response is durable in patients with chronic hepatitis C treated with peginterferon alfa-2a and ribavirin. Gastroenterol. Nov. 2010. 2010;139(5):1593-601. [pmid: 20637202].
8 Backus LI, Boothroyd DB, Phillips BR, et al. A sustained virologic response reduces risk of all-cause mortality in patients with hepatitis C. Clin Gastroenterol Hepatol. 2011;9:509-16. [pmid: 21397729].
9 Morgan TR, Ghany MG, Kim H-Y, et al. Outcome of sustained virological responders with histologically advanced chronic hepatitis C. Hepatology. Sep. 2010;52(3):833-44. [pmid: 20564351].
10 National Institutes of Health. National Institutes of Health consensus development conference statement: Management of hepatitis c: 2002--June 10–12, 2002. Hepatology. 2002;36(5 (Suppl 1)):S3-S20. [pmid: 12407572].
11 Ghany MG, Strader DB, Thomas DL, et al. Diagnosis, management, and treatment of hepatitis C: an update. Hepatology. 2009;49(4):1335-74. [pmid: 19330875].
12 Strader DB, Wright T, Thomas DL, et al. Diagnosis, management, and treatment of hepatitis C. Hepatology. 2004:1147-71. [pmid: 15057920].
13 Foster GR. Review article: pegylated interferons: chemical and clinical differences. Aliment Pharmacol Ther. Oct. 15. 2004;20(8):825-30. [pmid: 15479353].
14 Awad T, Thorlund K, Hauser G, et al. Peginterferon alpha-2a is associated with higher sustained virological response than peginterferon alfa-2b in chronic hepatitis C: Systematic review of randomized trials. Hepatology. 2010;51(4):1176-84. [pmid: 20187106].
15 Chou R, Carson S, Chan BKS, Care B. Drug Class Review on Pegylated Interferons for Chronic Hepatitis C Infection. Portland, OR. Oregon Health & Science University. 2007. www.ncbi.nlm.nih.gov/books/NBK10662/pdf/TOC.pdf. Accessed June 1, 2012.
16 Ascione A, De Luca M, Tartaglione MT, et al. Peginterferon alfa-2a plus ribavirin is more effective than peginterferon alfa-2b plus ribavirin for treating chronic hepatitis C virus infection. Gastroenterol. Jan. 2010;138(1):116-22. [pmid: 19852964].
17 Escudero A, Rodriguez F, Serra MA, et al. Pegylated alpha-interferon-2a plus ribavirin compared with pegylated alpha-interferon-2b plus ribavirin for initial treatment of chronic hepatitis C virus: prospective, non-randomized study. J Gastroenterol Hepatol. Jun. 2008;23(6):861-6. [pmid: 18422960].
18 McHutchison JG, Lawitz EJ, Shiffman ML, et al. Peginterferon alfa-2b or alfa-2a with ribavirin for treatment of hepatitis C infection. N Engl J Med. 2009;361(6):580-93. [pmid: 19625712].
19 Rumi MG, Aghemo A, Prati GM, et al. Randomized study of peginterferon-alpha2a plus ribavirin vs peginterferon-alpha2b plus ribavirin in chronic hepatitis C. Gastroenterol. Jan. 2010;138(1):108-15. [pmid: 19766645].
20 Nainan OV, Alter MJ, Kruszon-Moran D, et al. Hepatitis C virus genotypes and viral concentratiosn in participants of a general population survey in the United States. Gastroenterol. 2006;131:478-84. [pmid: 16890602].
21 Ge D, Fellay J, Thompson AJ, et al. Genetic variation in IL28B predicts hepatitis C treatment-induced viral clearance. Nature. 2009;461(7262):399-401. [pmid: 19684573].
22 Suppiah V, Moldovan M, Ahlenstiel G, et al. IL28B is associated with response to chronic hepatitis C interferon-α and ribavirin therapy. Nat Genet. 2009;41(10):1100-4. [pmid: 19749758].
23 Fried MW. Side effects of therapy of hepatitis C and their management. Hepatology. Nov. 2002;36(5 Suppl 1):S237-44. [pmid: 12407599].
24 FDA. Approval of Victrelis (boceprevir) a direct acting antiviral drug (DAA) to treat hepatitis C virus (HCV). 2011. www.fda.gov/ForConsumers/ByAudience/ForPatientAdvocates/ucm255413.htm. Accessed June 1 2012.
25 FDA. Approval of Incivek (telaprevir), a direct acting antiviral drug (DAA) to treat hepatitis C (HCV). 2011. www.fda.gov/ForConsumers/ByAudience/ForPatientAdvocates/ucm256328.htm. Accessed June 1, 2012.
26 Kwo PY, Lawitz EJ, McCone J, et al. Efficacy of boceprevir, an NS3 protease inhibitor, in combination with peginterferon alfa-2b and ribavirin in treatment-naive patients with genotype 1 hepatitis C infection (SPRINT-1): an open-label, randomised, multicentre phase 2 trial. [Erratum appears in Lancet. 2010 Oct 9;376(9748):1224 Note: SPRINT-1 investigators [added]; multiple investigator names added]. Lancet. Aug. 28. 2010;376(9742):705-16. [pmid: 20692693].
27 McHutchison JG, Everson GT, Gordon SC, et al. Telaprevir with peginterferon and ribavirin for chronic HCV genotype 1 infection. [Erratum appears in N Engl J Med. 2009 Oct 8;361(15):1516]. N Engl J Med. Apr. 30. 2009;360(18):1827-38. [pmid: 19403902].
28 Poordad F, Lawitz E, Shiffman ML, et al. Virologic response rates of weight-based taribavirin versus ribavirin in treatment-naive patients with genotype 1 chronic hepatitis C. Hepatology. Oct. 2010;52(4):1208-15. [pmid: 20721883].
29 Chou R, Hartung D, Rahman B, Wasson N, Cottrell E, Fu R. Treatment for Hepatitis C Virus Infection in Adults. Comparative Effectiveness Review No. 76. (Prepared by Oregon Evidence-based Practice Center under Contract No. 290-2007-10057-I). AHRQ Publication No. 12(13)-EHC113-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
30 Lok A. Preliminary study of two antiviral agents for hepatitis C genotype 1. N Engl J Med. 2012;366(3):273-5. [pmid: 22256811].
31 Carey T, Sanders GD, Viswanathan M, et al. Framework for Considering Study Designs for Future Research Needs. Methods Future Research Needs Paper No. 8. (Prepared by the RTI–UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I). AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm. 2012. [pmid: 22624168].
32 Chang SM, Carey T, Kato EU, et al. Identifying Research Needs for Improving Health Care. Ann Intern Med. Jul. 31. 2012;31(10):0003-4819. [pmid: 22847017].
33 Novartis. Pharmaceuticals. Available at: www.novartis.com/downloads/newsroom/corporate-fact-sheet/2a_Pharmaceuticals_EN.pdf. 2012.
34 Chou R, Cottrell EB, Wasson N, Rahman B, Guise JM. Screening for Hepatitis C Virus Infection in Adults. Comparative Effectiveness Review No. 69. (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-2007-10057-I). AHRQ Publication No. 12(13)-EHC090-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
35 Andriulli A, Persico M, Iacobellis A, et al. Treatment of patients with HCV infection with or without liver biopsy. J Viral Hepat. 2004;11(6):536-42. [pmid: 15500554].