# Methods

The specific steps used for this Future Research Needs report on antiviral treatment of HCV infection in adults are depicted and described in the flow diagram (Figure 2).

Figure 2 Flow diagram of methods

Note: CER = Comparative Effectiveness Review

This figure is a flow chart that methods for conducting the Future Research Needs review. The figure details nine steps of the review process: step 1, review CER; step 2, solicit insights from CER authors; step 3, review key informant and technical expert panel notes from the CER processes; step 4, invite stakeholders from various perspectives to participate in the Future Research Needs Report; step 5, presentation of materials to stakeholders, including followup discussion and incorporation of feedback; step 6, evidence gap prioritization and consensus processes using the Delphi method to sort research gaps into top tier and second tier research needs; step 7, search for ongoing or recently completed studies of top tier research needs; step 8, refinement of top tier research needs; and step 9, proposal of study designs to address top tier research needs.

## Identification of Evidence Gaps

We began by generating an initial list of evidence gaps as identified in the CER. The Principal Investigator of this Future Research Needs report also served as the Principal Investigator of the CER and provided insight into the identified future research needs. We reviewed all notes available from Key Informant interviews and Technical Expert Panel discussions undertaken as part of the CER processes. Stakeholder input was then solicited and used to identify additional evidence gaps, which were also organized around the PICOT framework, and subsequently prioritized into a top-tier list of research needs. This was accomplished through an initial Webinar and phone discussion with stakeholders, followed by two rounds of Web-based prioritization using stakeholder questionnaires, based on the Delphi method. SurveyMonkey™ was used to create and deliver the surveys and organize stakeholder responses. The top five gaps that received the most stakeholder endorsements were to be classified as the top-tier research needs, followed by the second-tier gaps. Gaps raised by the stakeholders that fell outside the scope of the CER were not prioritized, but are discussed.

## Criteria for Prioritization

After establishing a list of potential evidence gaps, the research team developed two prioritization questionnaires, which were tested internally for clarity and ease of use.

For the initial questionnaire (available in Appendix A), we asked the stakeholders to consider the following criteria when ranking gaps as high, medium, or low priority:

- Burden of disease
- High public interest
- Vulnerable populations
- Utilization of existing resources
- Potential impact
- Their own, additional reasoning.

We also asked stakeholders to describe their stakeholder perspective(s) and to describe any additional gaps missing and that they thought were most important.

In the second and final questionnaire (available in Appendix B), we asked the stakeholders to rank the evidence gaps in order of priority, using the Effective Health Care (EHC) Program Selection Criteria to help rank clinical importance/significance. The EHC Program Selection Criteria include the following:

### Appropriateness

- Represents a health care drug, intervention, device, technology, or health care system/setting available (or soon to be available) in the United States.
- Relevant to 1,013 enrollees (Medicare, Medicaid, State Children’s Health Insurance Program [SCHIP], other Federal health care programs).
- Represents one of the priority conditions designated by the U.S. Department of Health and Human Services.

### Importance

- Represents a significant disease burden, large proportion or priority population.
- Is of high public interest; affects health care decisionmaking, outcomes, or costs for a large proportion of the U.S. population or for a priority population in particular.
- Was nominated/strongly supported by one or more stakeholder groups.
- Represents important uncertainty for decisionmakers.
- Incorporates issues around both clinical benefits and potential clinical harms.
- Represents important variation in clinical care or controversy in what constitutes appropriate clinical care.
- Represents high costs to consumers, patients, health care systems or payers due to common use, high unit costs, or high associated costs.

### Desirability of New Research/Duplication

- Would not be redundant (i.e., the proposed topic is not already covered by available or soon-to-be available high-quality systematic review by the AHRQ or others).

### Feasibility

- Effectively uses existing research and knowledge by considering adequacy of research for conducting a systematic review and newly-available evidence.

### Potential Impact

- Potential for significant health impact, significant economic impact, potential change, potential risk from inaction, addressing inequities and vulnerable populations, and/or addressing a topic with clear implications for resolving important dilemmas in health and health care decisions made by one or more stakeholder groups.

We used the Delphi method for prioritization and consensus. In the Delphi method, input is sought from all stakeholders and information derived from prior communications is included in subsequent prioritization steps; therefore all stakeholders receive equal representation in the prioritization and consensus process. We decided a priori that prioritization would be repeated for no more than three rounds. For the initial round, we weighted the scores based on how many stakeholders endorsed the gap multiplied by a score based on the priority category high=3, medium=2, low=1, and then the gaps were ordered highest score to lowest score. The gaps with high and medium scores (≥14 out of a possible 21) were included in the next survey and gaps with lower scores were removed from further prioritization. For the next round, each stakeholder ranked the remaining priorities from highest priority (1) to lowest priority. The final prioritization was based on the total priority score, which was the sum of priority scores across all stakeholders. The research gaps with the lowest scores indicated the highest priority gaps. We did not conduct a third round of prioritization because the second round identified a sufficient number of research needs that received higher priority scores, using a cut-off score of 40. These top five gaps were to become the tier one research needs, and the remaining gaps were to be classified as second-tier research needs.

## Search for Ongoing or Recently Completed Studies

For the top-tier research needs, a research librarian searched the Ovid pre-MEDLINE, MEDLINE, and the Cochrane Central Register of Controlled Trials databases using the search strings developed for the original CER (Appendix C). The searches for the CER were conducted through August 2012. The librarian also searched for ongoing studies relevant to the identified research gaps using ClinicalTrials.gov and Current Controlled Trials.

## Engagement of Stakeholders From Various Perspectives

We engaged stakeholders from a variety of perspectives to identify important evidence gaps and prioritize future research needs. Stakeholders included a mix of both non-Federal and Federal clinicians, researchers, research funders, policymakers, payers, and consumer advocates. We attempted to have at least one stakeholder represent each of these perspectives on the panel, while ensuring that the panel included clinicians and researchers with the expertise and background to understand and evaluate the evidence gaps. Some stakeholders also served as Key Informants and Technical Experts for the CER. We submitted a list of proposed stakeholders to AHRQ. Following approval by AHRQ, we invited stakeholders to participate via email solicitations. Stakeholders who agreed to participate submitted conflict of interest statements. Conflicts of interest were evaluated and subject to approval by both our team and AHRQ.

In addition, we submitted the project protocol to the Oregon Health & Science University Institutional Review Board (IRB). The IRB reviewed and authorized the project to proceed as exempt from human subject research.

We hosted a Web-based presentation and conference call (Webinar) to orient stakeholders to the project and the major findings, limitations, and research gaps identified in the CER. The full text of the CER, the slides for the presentation, and orientation materials were sent to stakeholders prior to the phone meeting. Following the presentation, we facilitated a discussion among the stakeholders to generate a list of additional research gaps and to gain feedback on the previously identified gaps. We requested specific feedback for each domain of the PICOT framework, and provided time for additional open-ended feedback. Following the Webinar and associated discussion, we circulated questionnaires to the stakeholders to collect thoughts on current and additional gaps, as well as input on prioritization.

The Future Research Needs report will be publically posted for a period of 4 weeks, during which anyone can provide feedback. The stakeholders will be informed of the posting period.

## Research Design Considerations and Research Questions

As a final step, our research team proposed study designs to address the top research needs using a recent study design guidance framework.31 We considered the following factors at this final phase:

- Ability to produce a valid result
- Resource use
- Ethical factors
- Data availability
- Recruitment feasibility

We also provided example research questions and accompanying PICOT specifications.