# Stakeholder Representatives

- Kirstin Bibbins-Domingo, Ph.D., M.D.
  Associate Professor in Residence
  University of California San Francisco School of Medicine
  San Francisco, CA
- Joseph Chin, M.D., M.S.
  Medical Officer, Coverage and Analysis Group
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Michael Ninburg, M.P.A.
  Executive Director
  Hepatitis Education Project
  Seattle, WA
- Bruce Runyon, M.D.
  Clinical Professor of Medicine and Director of Hepatology
  University of California Los Angeles
  Los Angeles, CA
- Donna Sweet, M.D., MACP, AAHIVS
  Professor of Medicine and Director of Internal Medicine Education
  University of Kansas Medical Center
  Kansas City, KS
- John Ward, M.D.
  Director of the Division of Viral Hepatitis
  Centers for Disease Control and Prevention
  Atlanta, GA
- John B. Wong, M.D.
  Chief of the Division of Clinical Decision Making, Informatics, and Telemedicine
  Tufts Medical Center
  Boston, MA