# Acknowledgments

The Oregon Evidence-based Practice Center would like to acknowledge the Stakeholders who volunteered their time and provided thoughtful insights for this report, as well as the Agency for Healthcare Research and Quality Task Order Officer of this report, Christine Chang, M.D., M.P.H.