# Discussion

Based on the 2012 CER, and with the input of stakeholders, we identified 12 evidence gaps, seven of which were prioritized as top-tier research needs, and the remainder as second-tier research needs based on the priority rankings of stakeholders. Most of the research gaps did not suggest new research questions to be addressed; rather they primarily identified the need for more applicable and methodologically rigorous studies; therefore the research questions provided are examples. In fact, a number of the research gaps (such as the need for studies that evaluate an effectiveness paradigm, studies that evaluate patients with important comorbidities, and studies that are not funded by the pharmaceutical industry) are relevant across many research questions applicable to understanding the comparative effectiveness of antiviral treatments for HCV.

A limitation of our report is the omission of potentially important research needs due to the requirement of the needs to be within the scope of the original CER. For example, the CER did not evaluate patients with HIV or hepatitis B virus coinfection, or patients who had previously been treated for HCV infection. It also excluded children. Because the CER did not evaluate the state of the evidence for these populations, the extent of research gaps and availability of research was not known. Such areas could be the subject of nominations for future CERs in the EHC program. The precedent for this limitation was initially discussed with the stakeholders during the webinar, which precluded any out of scope gaps from being raised at subsequent opportunities.

Another limitation is that we also had a small sample of stakeholders, with limited representation of some stakeholder perspectives. In addition, standardized and validated methods for selecting stakeholders and synthesize diverse stakeholder viewpoints are not yet available, but would be helpful for Future Research Needs projects.

The rapidly evolving nature of antiviral HCV treatments suggests that even a CER completed this year will need to be updated in the near future. Stakeholders emphasized that all-oral, interferon-sparing regimens are expected within the next few years and will likely have a major impact on clinical practice.