# Background

## Context

Future Research Needs reports are intended to inform and support researchers and those who fund research to ultimately enhance the body of comparative effectiveness evidence so that it is useful for decisionmakers. This Future Research Needs report focuses on developing and prioritizing the most pressing research needs around antiviral treatment of hepatitis C virus (HCV) infection in adults.

HCV is the most common chronic blood-borne pathogen in the United States. HCV is primarily acquired by large or repeated percutaneous exposures to blood, with injection drug use the strongest risk factor. Based on a national survey of households, approximately 1.6 percent of U.S. adults over 20 years of age have antibodies to HCV, indicating prior acute HCV infection.1 About 78 percent of patients with acute HCV infection develop chronic HCV infection, defined by the presence of persistent viremia.

Chronic HCV infection has a variable course, but it is a leading cause of complications from chronic liver disease, including cirrhosis, liver failure, and hepatocellular cancer. Chronic HCV infection is associated with an estimated 15,000 deaths each year in the United States,2 and it is the most common indication for liver transplantation among American adults, accounting for more than 30 percent of cases.3 The prevalence of chronic HCV infection is thought to have peaked in 2001 at 3.6 million people and the yearly incidence has declined from more than 200,000 cases per year in the 1980s to around 16,000 cases in 2009.^4,5^ However, complications related to chronic HCV infection, which frequently occur only after decades of infection, are expected to rise for another 10 to 13 years.4

The goals of antiviral treatment for chronic HCV infection are to prevent the long-term health complications associated with HCV infection such as cirrhosis, hepatic decompensation, and liver cancer, but it is extremely difficult to design and carry out clinical trials long and large enough to provide direct evidence related to these outcomes. The sustained virologic response (SVR) rate, typically defined as a decline in HCV RNA to undetectable levels 24 weeks following completion of antiviral treatment, is the standard marker of successful treatment in clinical trials because it is strongly associated with long-term absence of viremia.6,7 Recent studies have evaluated the association between achieving an SVR and reductions in mortality, liver failure, and cancer.8,9

In the early 2000s, the combination of “pegylated” interferon plus ribavirin became the standard antiviral treatment for HCV infection.10–12 Pegylation refers to the cross-linking of polyethylene glycol molecules to the interferon molecule, which delays renal clearance and thereby permits less frequent dosing (once weekly vs. three times a week with standard interferon).13 Dual therapy with pegylated interferon plus ribavirin is associated with higher SVR rates (about 55 to 60 percent overall) than either standard interferon plus ribavirin or pegylated interferon monotherapy. Currently, two pegylated interferons are available: pegylated interferon alfa-2a and pegylated interferon alfa-2b. Although previous reviews found insufficient evidence to determine whether combination therapy with pegylated interferon alfa-2a or pegylated interferon alfa-2b plus ribavirin is more effective,14,15 more head-to-head trials directly comparing these two regimens are now available.16–19

A number of factors affect response to antiviral treatment. The two major pretreatment predictors of SVR are the viral genotype and the pretreatment viral load.11 In the United States, genotype 1 infection is found in around three-quarters of HCV-infected patients.20 HCV genotype 1 infection is associated with a substantially lower response to antiviral treatment than infection with genotypes 2 and 3, which are present in about 20 percent of HCV-infected patients. A pretreatment viral load of <600,000 IU/mL is associated with higher likelihood of achieving an SVR.11 Other factors less consistently or less strongly associated with increased likelihood of SVR include female sex, age less than 40 years, non-African-American race, lower body weight (≤75 kg), absence of insulin resistance, elevated alanine aminotransferase levels, and absence of bridging fibrosis or cirrhosis on liver biopsy.11 Effects of race on the likelihood of SVR may be due in part to polymorphisms in the interleukin-28B (IL28B) gene.21,22

An issue complicating antiviral treatment is the high rate of adverse effects observed with interferon-based therapy, including flu-like symptoms, fatigue, and neuropsychiatric and hematologic adverse effects.23 Such adverse effects can be difficult to tolerate and can lead to premature discontinuation of therapy.

In 2011, the U.S. Food and Drug Administration (FDA) approved the first direct acting antiviral agents, boceprevir (trade name Victrelis^®^) and telaprevir (trade name Incivek^®^), for treatment of chronic HCV genotype 1 infection.24,25 Both drugs are classified as nonstructural 3/4A protease inhibitors, with a potential advantage of shorter duration of therapy (24 to 28 weeks) compared with standard dual therapy with pegylated interferon (alfa-2a or 2b) plus ribavirin for genotype 1 infection (48 weeks).26–28 Either drug is administered in combination with pegylated interferon (alfa-2a or 2b) plus ribavirin.

## Findings From Comparative Effectiveness Review

In 2010 the Agency for Healthcare Research and Quality (AHRQ) charged the Oregon Evidence-based Practice Center (EPC) with conducting a Comparative Effectiveness Review (CER)29 on antiviral treatments for HCV infection. The CER will be published in 2012 and searches for the review were conducted through August, 2012. The CER focused on current FDA-approved antiviral therapies for antiviral-naïve adults with chronic HCV infection, without HIV or hepatitis B virus coinfection.

The Key Questions addressed in the CER were:

### Key Question 1

1a What is the comparative effectiveness of antiviral treatment in improving health outcomes in patients with HCV infection?
1b How does the comparative effectiveness of antiviral treatment for health outcomes vary according to patient subgroup characteristics, including but not limited to HCV genotype, age, race, sex, stage of disease, or genetic markers?

### Key Question 2

2a What is the comparative effectiveness of antiviral treatments on intermediate outcomes, such as the rate of SVR or histologic changes in the liver?
2b How does the comparative effectiveness of antiviral treatment for intermediate outcomes vary according to patient subgroup characteristics, including but not limited to HCV genotype, age, race, sex, stage of disease, or genetic markers?

### Key Question 3

3a What are the comparative harms associated with antiviral treatments?
3b Do these harms differ according to patient subgroup characteristics, including but not limited to HCV genotype, age, race, sex, stage of disease, or genetic markers?

### Key Question 4

4 Have improvements in intermediate outcomes (SVR, histologic changes) been shown to reduce the risk or rates of adverse health outcomes from HCV infection?

The analytic framework (Figure 1) illustrates the targeted population, interventions, and outcomes for the CER. The numbers in the figure refer to the numbers of the Key Questions.

Figure 1 Analytic framework from Comparative Effectiveness Review

Note: HCV=hepatitis C virus, QOL=quality of life, SVR=sustained virologic response.

This figure depicts the analytic framework that outlines the population, interventions and outcomes considered in the review. The above figure is a modified version of a larger framework depicting the impact of both screening and treatment for Hepatitis C in adults. This figure focuses on the treatment portion of the framework. The population includes adult patients with chronic hepatitis C virus (HCV) infection. The interventions include pegylated interferon alfa-2a with ribavirin; pegylated interferon alfa-2b with ribavirin; protease inhibitors pending FDA approval (e.g., telaprevir). Intermediate outcomes include liver function, sustained virologic remission, and histologic improvements. Final outcomes include morbidity and mortality from HCV (including hepatic cirrhosis, hepatocellular carcinoma, liver transplantation rates, quality of life); harms of antiviral therapies including flu-like symptoms, hematologic effects, psychiatric effects. Outcomes also include “quality of life” and “transmission of hepatitis C virus”.

The objectives of the CER were to understand the comparative benefits and harms of the various antiviral regimens to make informed treatment decisions in antiviral-naïve patients with chronic HCV infection, particularly given the availability of new treatment options. The review assessed the comparative effectiveness of antiviral treatments in adults with chronic HCV infection who have not received previous antiviral drug treatment. In addition to assessing the comparative effectiveness of different drug regimens, the review evaluated effects of different medication doses, durations of therapy, and dosing strategies (such as weight-based or response-guided vs. fixed treatment), and how comparative effectiveness varies depending on HCV genotype, viral load, and other demographic and clinical characteristics. The CER did not evaluate antiviral treatment of HCV-infected patients with HIV or hepatitis B coinfection, pregnant women, or children.

The results of the CER are summarized in the Summary of Evidence table (Table 1).

Table 1 Summary of evidence table from the comparative effectiveness review

Key Question | Outcome | Summary of Evidence | Strength of Evidence
Key Question 1a. What is the comparative effectiveness of antiviral treatment in improving health outcomes in patients with HCV infection? | Long-term clinical outcomes | No evidence. | Insufficient
Key Question 1a. What is the comparative effectiveness of antiviral treatment in improving health outcomes in patients with HCV infection? | Short-term mortality | Three trials that compared current antiviral regimens^a^ found no differences in risk of short-term mortality, but reported few (20 total) events. | Low
Key Question 1a. What is the comparative effectiveness of antiviral treatment in improving health outcomes in patients with HCV infection? | Short-term quality of life | One open-label randomized trial of patients with genotype 4 infection found dual therapy with pegylated interferon alfa-2a plus ribavirin associated with statistically significant, slightly better short-term scores on some quality of life assessments compared with dual therapy with pegylated interferon alfa-2b plus ribavirin. | Low
Key Question 1b. How does the comparative effectiveness of antiviral treatment for health outcomes vary according to patient subgroup characteristics? | Any clinical outcome | No evidence. | Insufficient
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | | Dual therapy with pegylated interferon alfa-2b plus ribavirin vs. dual therapy with pegylated interferon alfa-2a plus ribavirin
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | Seven trials found dual therapy with standard doses of pegylated interferon alfa-2b plus ribavirin associated with lower likelihood of achieving an SVR than pegylated interferon alfa-2a plus ribavirin (pooled RR 0.87, 95% CI, 0.80 to 0.95; I^2^=27%), with an absolute difference in SVR rates of 8 percentage points (95% CI, 3 to 14). | Moderate
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | | Dual therapy with pegylated interferon alfa-2a or alfa-2b plus ribavirin: duration effects
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | Two trials of patients with genotype 2 or 3 infection found no difference in likelihood of achieving an SVR between 48 vs. 24 weeks of dual therapy with pegylated interferon alfa-2a plus ribavirin (pooled RR 0.97, 95% CI, 0.84 to 1.1; I^2^=43%). | Moderate
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | Four trials of patients with genotype 2 or 3 infection found 24 weeks of dual therapy with pegylated interferon (alfa-2a or alfa-2b) more effective than 12–16 weeks for achieving an SVR (pooled RR 1.2, 95% CI, 1.0 to 1.3; I^2^=80%). Relative risk estimates ranged from 1.0 to 1.3 in the four trials and may have varied in part due to differences across studies in ribavirin dosing. | Moderate
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | Three trials of patients with genotype 2 or 3 infection with a rapid virologic response (undetectable HCV-RNA by week 4) found no differences between 24 vs. 12–16 weeks of dual therapy with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin (pooled RR 0.99, 95% CI, 0.86 to 1.1, I^2^=66%). Relative risk estimates ranged from 0.89 to 1.1. | Moderate
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | | Dual therapy with pegylated interferon alfa-2a or alfa-2b plus ribavirin: dose effects
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | Six trials of patients with genotype 2 or 3 infection found lower doses of pegylated interferon alfa-2b (0.75–1.0 mcg/kg or 50 mcg) associated with lower likelihood of achieving an SVR than higher doses (1.5 mcg/kg or 100–150 mcg) (pooled RR 0.90; 95% CI, 0.81 to 0.99; I^2^=20%). | Moderate
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | Three trials of patients with genotype 2 or 3 infection who did not specifically have advanced fibrosis or cirrhosis found no clear difference in likelihood of SVR between lower doses of ribavirin (400 or 800 mg flat dose or 600 to 800 mg weight-based dose) vs. higher doses (800 or 1,200 mg flat dose or 800 to 1400 mg weight-based dose). | Moderate
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | One small trial of patients with genotype 2 or 3 infection (n=97) and advanced fibrosis or cirrhosis (Ishak stage 4–6) found 600 to 800 mg daily of ribavirin associated with lower likelihood of SVR than 1000 to 1200 mg daily (45 vs. 72 percent, RR 0.62, 95% CI, 0.40 to 0.98). | Low
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | | Triple therapy with pegylated interferon alfa-2b, ribavirin, and boceprevir vs. dual therapy with pegylated interferon alfa-2b plus ribavirin
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | Two trials of patients with genotype 1 infection found triple therapy with boceprevir (pegylated interferon alfa-2b plus ribavirin for 4 weeks, followed by the addition of boceprevir for 44 weeks) associated with higher likelihood of SVR than dual therapy with pegylated interferon alfa-2b plus ribavirin therapy for 48 weeks (pooled RR 1.8; 95% CI, 1.6 to 2.1; I^2^=0%), with an absolute increase in SVR rate of 31% (95% CI, 23 to 39). | Moderate
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | One trial of patients with genotype 1 infection found 48 weeks of triple therapy with boceprevir using a low dose of ribavirin (400–1000 mg daily) associated with a non–statistically significant trend toward lower likelihood of SVR compared with 48 weeks of triple therapy with a standard ribavirin dose (800–1400 mg daily) (36% vs. 50%, RR 0.71, 95% CI, 0.39 to 1.3). | Low
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | | Triple therapy with pegylated interferon (alfa-2a or alfa-2b), ribavirin, and telaprevir vs. dual therapy with pegylated interferon alfa-(-2a or alfa-2b) plus ribavirin
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | Three trials of patients with genotype 1 infection found triple therapy with telaprevir for 24 weeks (12 weeks of pegylated interferon alfa-2a, ribavirin, and telaprevir followed by 12 weeks of pegylated interferon alfa-2a plus ribavirin) associated with a higher likelihood of SVR than dual therapy with pegylated interferon alfa-2a plus ribavirin for 48 weeks (pooled RR 1.5, 95% CI, 1.3 to 1.8; I^2^=0%), with an absolute increase in SVR rate of 22% (95% CI, 13 to 31). | Moderate
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | One trial of patients with genotype 1 infection found no difference in likelihood of SVR between triple therapy with pegylated interferon, ribavirin, and telaprevir for 12 weeks vs. dual therapy with pegylated interferon alfa-2a plus ribavirin for 48 weeks. | Moderate
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | One trial of patients with genotype 1 infection found response-guided triple therapy with telaprevir (pegylated interferon alfa-2a, ribavirin, and telaprevir for 8 or 12 weeks followed by a response-guided dual therapy with pegylated interferon alfa-2a plus ribavirin for an additional 12 or 36 weeks) associated with a higher likelihood of SVR than dual therapy with pegylated interferon alfa-2a plus ribavirin for 48 weeks (RR 1.6, 95% CI, 1.4 to 1.9), with an absolute increase in SVR rate ranging from 25% to 31%. The regimen with 8 weeks of telaprevir was associated with a slightly lower SVR rate than the 12 week telaprevir regimen (69% vs. 75%). | Low
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | One trial of patients with genotype 1 infection found no difference in likelihood of SVR between triple therapy with telaprevir for 48 weeks (12 weeks of triple therapy with pegylated interferon alfa-2a, ribavirin, and telaprevir followed by 36 weeks of dual therapy with pegylated interferon alfa-2a plus ribavirin) vs. triple therapy with telaprevir for 24 weeks (12 weeks of triple therapy followed by 12 weeks of dual therapy). | Low
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Triple therapy with pegylated interferon alfa-2a, ribavirin, and telaprevir: dose effects of pegylated interferon alfa-2a vs. -2b and duration effects
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | One trial of response-guided triple therapy with telaprevir (24 or 48 weeks, based on absence or presence of HCV-RNA from weeks 4 through 20) found similar SVR rates (81–85%) for regimens that varied on telaprevir dose (750 mg tid vs. 1125 mg bid) and type of pegylated interferon (alfa-2a or alfa-2b). | Low
Key Question 2a. What is the comparative effectiveness of antiviral treatments on intermediate outcomes? | Sustained virologic response | One trial of patients with an extended rapid virologic response to initial triple therapy with telaprevir reported similar, high (92% and 88%) SVR rates in patients randomized to a total of 24 or 48 weeks of therapy. | Low
Key Question 2b. How does the comparative effectiveness of antiviral treatment for intermediate outcomes vary according to patient subgroup characteristics? | Dual therapy with pegylated interferon alfa-2b plus ribavirin vs. dual therapy with pegylated interferon alfa-2a plus ribavirin
Key Question 2b. How does the comparative effectiveness of antiviral treatment for intermediate outcomes vary according to patient subgroup characteristics? | Sustained virologic response | The largest randomized trial (n=3070) of dual therapy with pegylated interferon alfa-2a plus ribavirin vs. dual therapy with pegylated interferon alfa-2b plus ribavirin found no clear differences in relative risk estimates for SVR in genotype 1 patients stratified by race, sex, age, baseline fibrosis stage, or baseline viral load. Characteristics associated with lower absolute SVR rates across dual therapy regimens were older age, Black race, advanced fibrosis or cirrhosis, and high baseline viral load. | Low
Key Question 2b. How does the comparative effectiveness of antiviral treatment for intermediate outcomes vary according to patient subgroup characteristics? | Sustained virologic response | Four randomized trials of dual therapy with pegylated interferon alfa-2a plus ribavirin vs. dual therapy with pegylated interferon alfa-2b plus ribavirin found no clear differences in relative risk estimates for SVR in patients stratified by genotype. Genotype 1 infection was associated with a lower absolute SVR rate than genotypes 2 or 3. | Moderate
Key Question 2b. How does the comparative effectiveness of antiviral treatment for intermediate outcomes vary according to patient subgroup characteristics? | Triple therapy with pegylated interferon alfa-2b, ribavirin, and boceprevir vs. dual therapy with pegylated interferon alfa-2b plus ribavirin
Key Question 2b. How does the comparative effectiveness of antiviral treatment for intermediate outcomes vary according to patient subgroup characteristics? | Sustained virologic response | Two trials of triple therapy with boceprevir for 48 weeks (4 weeks of dual therapy lead-in with pegylated interferon plus ribavirin followed by 44 weeks of triple therapy with pegylated interferon, ribavirin, and boceprevir) found no difference in relative risk estimates for SVR in men vs. women, and no clear difference in relative risk estimates for Black vs. non-Black patients. Black race was associated with a lower absolute SVR rate than non-Black race. | Moderate
Key Question 2b. How does the comparative effectiveness of antiviral treatment for intermediate outcomes vary according to patient subgroup characteristics? | Sustained virologic response | Two trials found triple therapy with pegylated interferon alfa-2b, ribavirin, and boceprevir associated with higher likelihood of achieving SVR than dual therapy with pegylated interferon alfa-2b plus ribavirin in patients with high baseline HCV-RNA viral load (>600,000 or ≥800,000 IU/mL), but found no difference in likelihood of SVR in patients with lower viral load. | Moderate
Key Question 2b. How does the comparative effectiveness of antiviral treatment for intermediate outcomes vary according to patient subgroup characteristics? | Triple therapy with pegylated interferon alfa-(-2a or alfa-2b), ribavirin, and telaprevir vs. dual therapy with pegylated interferon alfa (-2a or alfa-2b) plus ribavirin
Key Question 2b. How does the comparative effectiveness of antiviral treatment for intermediate outcomes vary according to patient subgroup characteristics? | Sustained virologic response | One trial of response-guided triple therapy with telaprevir (12 weeks of pegylated interferon alfa-2a, ribavirin, and telaprevir followed by response-guided dual therapy with pegylated interferon alfa-2a and ribavirin) vs. dual therapy with pegylated interferon plus ribavirin for 48 weeks found no clear differences in relative risk estimates in patients stratified by age, sex, race, baseline fibrosis status, or body mass index. Characteristics associated with lower absolute rates of SVR were older age, Black race, advanced fibrosis or cirrhosis, and higher body mass index. One other trial of 24-week fixed duration triple therapy with telaprevir, pegylated interferon alfa-2b, and ribavirin vs. 48 weeks of dual therapy found no differences in estimates of effect in patients stratified by sex or age. | Moderate (for age and sex) Low (for other factors)
Key Question 2b. How does the comparative effectiveness of antiviral treatment for intermediate outcomes vary according to patient subgroup characteristics? | Sustained virologic response | Two trials of triple therapy with pegylated interferon (alfa-2a or alfa-2b), ribavirin, and telaprevir vs. dual therapy depending reported inconsistent findings for differential relative risk estimates according baseline viral load. | Insufficient
Key Question 3a. What are the comparative harms associated with antiviral treatments? | Dual therapy with pegylated interferon alfa-2b plus ribavirin vs. dual therapy with pegylated interferon alfa-2a plus ribavirin
Key Question 3a. What are the comparative harms associated with antiviral treatments? | Harms | Dual therapy with pegylated interferon alfa-2b was associated with slightly greater risk of headache (three trials, pooled RR 1.1, 95% CI, 1.1 to 1.2, I^2^=0%), and a lower risk of serious adverse events (two trials, pooled RR 0.74; 95% CI, 0.57 to 0.95; I^2^=0%), lower risk of neutropenia (five trials, pooled RR 0.60, 95% CI, 0.46 to 0.83), and lower risk of rash (two trials, pooled RR 0.79, 95% CI, 0.71 to 0.88, I^2^=0%) than dual therapy with pegylated interferon alfa-2a plus ribavirin, with no differences in withdrawals due to adverse events. | Moderate
Key Question 3a. What are the comparative harms associated with antiviral treatments? | Triple therapy with pegylated interferon alfa-2b, ribavirin, and boceprevir vs. dual therapy with pegylated interferon alfa-2b plus ribavirin
Key Question 3a. What are the comparative harms associated with antiviral treatments? | Harms | Triple therapy with boceprevir for 48 weeks (pegylated interferon alfa-2b plus ribavirin for 4 weeks followed by addition of boceprevir for 44 weeks) was associated with increased risk of neutropenia (two trials, pooled RR 1.8, 95% CI, 1.5 to 2.3, I^2^=0%), dysgeusia (two trials, pooled RR 2.5, 95% CI, 2.0 to 3.2, I^2^=0%), anemia (two trials, pooled RR 2.0, 95% CI, 1.4 to 2.8, I^2^=0%), and thrombocytopenia (two trials, pooled RR 3.3, 95% CI, 1.3 to 8.6) than dual therapy with pegylated interferon alfa-2b plus ribavirin. The incidence of anemia was about 50% with triple therapy and the incidence of neutropenia about 25%, with severe anemia in 4–5% and severe neutropenia in 8–15%. | Moderate
Key Question 3a. What are the comparative harms associated with antiviral treatments? | Triple therapy with pegylated interferon alfa (-2a or -2b), ribavirin, and telaprevir vs. dual therapy with pegylated interferon alfa-(-2a or -2b) plus ribavirin
Key Question 3a. What are the comparative harms associated with antiviral treatments? | Harms | In two trials, there were no statistically significant differences between a 12-week regimen of triple therapy with pegylated interferon alfa-2a, ribavirin, and telaprevir vs. dual therapy with pegylated interferon alfa-2a plus ribavirin in risk of any assessed adverse event. | Moderate
Key Question 3a. What are the comparative harms associated with antiviral treatments? | Harms | In three trials, a 24-week regimen of triple therapy with telaprevir (pegylated interferon alfa-2a or alfa-2b, ribavirin, and telaprevir for 12 weeks followed by pegylated interferon alfa-2a plus ribavirin for 12 weeks) was associated with increased risk of anemia (three trials, pooled RR 1.3, 95% CI, 1.1 to 1.5, I^2^=0%) and rash (three trials, pooled RR 1.4, 95% CI, 1.1 to 1.7) vs. dual therapy with pegylated interferon alfa-2a plus ribavirin for 48 weeks. Among patients randomized to the 24-week telaprevir regimen, one to two-thirds experienced a rash (7–10% experienced severe rash) and 27–91% experienced anemia (4–11% experienced severe anemia). There was no difference in risk of withdrawal due to adverse events. | Moderate
Key Question 3a. What are the comparative harms associated with antiviral treatments? | Harms | In one trial, response-guided triple therapy with telaprevir (pegylated interferon alfa-2a, ribavirin, and telaprevir for 8 or 12 weeks followed by response-guided duration pegylated interferon alfa-2a and ribavirin) was associated with increased risk of withdrawal due to adverse events (27% vs. 7.2%, RR 3.8, 95% CI, 2.6 to 5.7), anemia (38% vs. 19%, RR 2.0, 95% CI, 1.6 to 2.5), any rash (36% vs. 24%, RR 1.5, 95% CI, 1.2 to 1.8), and severe rash (5% vs. 1%, RR 4.6, 95% CI, 1.6 to 13) vs. therapy with pegylated interferon alfa-2a plus ribavirin for 48 weeks. | Low
Key Question 3b. Do these harms differ according to patient subgroup characteristics? | Dual therapy with pegylated interferon alfa-2b plus ribavirin vs. dual therapy with pegylated interferon alfa-2a plus ribavirin
Key Question 3b. Do these harms differ according to patient subgroup characteristics? | Harms | No trial of dual therapy with pegylated interferon alfa-2b plus ribavirin vs. dual therapy with pegylated interferon alfa-2a plus ribavirin reported harms in patients stratified by factors such as HCV genotype, age, race, sex, stage of disease, or genetic markers. Three trials that restricted enrollment to patients with genotype 1 infection reported risk estimates for risk of harms that were similar to the risk estimates based on all trials. | Insufficient
| Triple therapy with pegylated interferon alfa-2a or alfa-2b, ribavirin, and telaprevir or boceprevir vs. dual therapy with pegylated interferon alfa-2a or alfa-2b plus ribavirin
| Harms | No trial evaluated harms associated with triple therapy with pegylated interferon, ribavirin, and boceprevir or telaprevir vs. dual therapy with pegylated interferon plus ribavirin in patient subgroups. All trials evaluated patients with genotype 1 infection. | Insufficient
Key Question 4. Have improvements in intermediate outcomes been shown to reduce the risk or rates of adverse health outcomes from HCV infection? | Mortality and long-term hepatic complications | A large VA hospital study that controlled well for potential confounders found an SVR after antiviral therapy associated with lower risk of all-cause mortality vs. no SVR (adjusted HR 0.71 [0.60–0.86], 0.62 [0.44–0.87] and 0.51 [0.35–0.75] for genotypes 1, 2, and 3, respectively). Eighteen other cohort studies found an SVR associated with decreased risk of all-cause mortality, liver-related mortality, HCC, and other complications of ESLD compared with no SVR, with stronger effect estimates than the VA study (adjusted HRs generally ranged from around 0.10 to 0.33). However, the studies had methodological shortcomings, including inadequate handling of confounders, and 10 were conducted in Asia. | Moderate
Key Question 4. Have improvements in intermediate outcomes been shown to reduce the risk or rates of adverse health outcomes from HCV infection? | Short-term quality of life | Nine studies found an SVR associated with greater improvement in measures related to quality of life (generic or disease-specific) 24 weeks after the end of antiviral treatment vs. no SVR, with differences averaging less than 5 to 10 points on various SF-36 domains. All studies were poor-quality and were characterized by failure to adjust for confounders, high loss to followup, and failure to blind patients to SVR status. | Low

Note: CI=confidence interval, ESLD=end-stage liver disease, HCC=hepatocellular carcinoma, HCV=hepatitis C virus, HCV-RNA=hepatitis C virus ribonucleic acid, HR=hazard ratio; I^2^=index measures the extent of true heterogeneity in a meta-analysis, RR=relative risk, SF-36= short-form health survey with 36 questions, SVR=sustained virologic response, VA=Veterans Affairs.

a “Current antiviral treatment regimen” refers to dual therapy with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin, or triple therapy with pegylated interferon (alfa-2a or alfa-2b) plus ribavirin and boceprevir or telaprevir.

Research gaps and limitations of the existing literature identified in the CER are summarized below, organized according to the most relevant elements of the population, intervention, comparator, outcome, and timing (PICOT) framework. Important contextual issues noted in the CER are also described.

### Evidence Gaps From Comparative Effectiveness Review

We organized the evidence gaps from the CER according to the PICOT framework:

#### Population-Related Gaps

1. Need for studies enrolling broader spectrum of patients, including those with medical and psychological comorbidities seen in clinical practice (relevant to all Key Questions).
2. Need for studies of treatment in screen-detected patients, to understand applicability to this population (relevant to all Key Questions).
3. Need for studies designed using an effectiveness paradigm, to understand real-world effects of antiviral regimens, including effects related to the poorer treatment adherence than observed in efficacy trials (relevant to all Key Questions).
4. Need for studies on effects of newer triple therapy regimens with a protease inhibitor in subgroups defined by age, body weight, baseline fibrosis stage, and other important factors (relevant to Key Questions 2b, 3b).

#### Intervention-Related Gaps

1. Need for head-to-head studies comparing triple therapy with newer protease inhibitors (telaprevir and boceprevir) (relevant to Key Questions 1a, 1b, 2a, 2b, 3a, and 3b).
2. Need for trials evaluating the boceprevir regimen approved by the FDA in antiviral-naïve patients without baseline cirrhosis (relevant to Key Questions 1a, 1b, 2a, 2b, 3a, and 3b).
3. Need for studies that evaluate the usefulness of genomics and other methods for individualizing treatment decisions in patients with HCV infection are also needed (relevant to Key Questions 1b, 2b, and 3b).

#### Comparator-Related Gaps

1. Need for more studies on clinical outcomes in patients who experience SVR following antiviral treatment versus those who do not experience SVR that are methodologically rigorous, including adequate controlling for potential confounders (relevant to Key Question 4).

#### Outcome/Timing-Related Gaps

1. Need for studies assessing important long-term clinical outcomes associated with current antiviral treatments for chronic HCV infection (relevant to Key Questions 1a and 1b).
2. Need for methodologically rigorous studies on effects of achieving a SVR on long-term quality of life (relevant to Key Question 4).
3. Need for studies with long-term followup of patients exposed to telaprevir and boceprevir to understand the long-term harms (relevant to Key Questions 3a and 3b).

#### Other Issues

1. Need for studies not funded by pharmaceutical companies, as almost all studies of antiviral therapies were funded by pharmaceutical companies; studies have found that industry-funded studies tend to report more favorable results than studies not funded by industry (relevant to all Key Questions).

### Known Ongoing Research From Comparative Effectiveness Review

A number of other protease inhibitors and other newer drugs for treatment of HCV infection are currently in active development and further studies with new drugs and drug regimens are expected, including all-oral, interferon-sparing regimens.30