# Search Strategy for Ongoing and Recently Completed Studies

## Ovid MEDLINE: Search Date Through August 28, 2012

Hepatitis C/ or Hepatitis C, Chronic/ or Hepacivirus/ or Hepatitis C.mp. or hepacivirus$.mp. or HCV.mp.

Antiviral agents/ or Interferons/ or Interferon-alpha/ or Interferon Alfa-2a/ or Interferon Alpha-2b/ or Interferon$.mp. or interferon alpha-2a.mp. or interferon alpha-2b.mp. or IFNalpha2a.mp. or IFNalpha2b.mp. or interferon alpha 2a.mp. or interferon alpha 2b.mp. or exp Polyethylene Glycols/ or pegasys.mp. or Peg-intron.mp. or peginterferon alpha-2a.mp. or peginterferon alpha-2b.mp. or peginterferon alpha 2a.mp. or peginterferon alpha 2b.mp. or pegylated interferon$.mp. or IFN$.mp. or PEG IFN$.mp. or Ribavirin/ or ribavirin.mp. or RBV.mp. or exp Protease Inhibitors/ or protease inhibitor$.mp. or polymerase inhibit$.mp. or HCV protease$.mp. or telaprevir.mp. or boceprevir.mp.

1 and 2

(randomized controlled trial or controlled clinical trial or meta analysis or review).pt. or clinical trials as topic/ or cohort studies/ or randomized.ab. or randomly.ab. or placebo.ab. or (systematic adj1 review).ti,ab.

3 and 4

limit 5 to (yr=“2002 -Current” and (“adult (19 to 44 years)” or “middle age (45 to 64 years)” or “all aged (65 and over)”))

(unsafe or safety or harm$ or complication$ or poison$ or risk$).mp. or AE.fs. or MO.fs. or PO.fs. or TO.fs. or CT.fs. or side-effect$.mp. or (undesirable adj1 effect$).mp. or (treatment adj1 emergent).mp. or tolerab$.mp. or toxic$.mp. or adrs.mp. or (adverse adj2 (effect or effects or reaction or reactions or event or events or outcome or outcomes)).mp.

1 and 2 and 7

4 and 8

limit 9 to (yr=“2002 -Current” and (“adult (19 to 44 years)” or “middle age (45 to 64 years)” or “all aged (65 and over)”))

Counseling/ or Sex Counseling/ or Health Education/ or Patient Education as Topic/ or Psychotherapy/ or Behavior Therapy/ or Cognitive Therapy/ or Immunization/ or Immunotherapy/ or Psychotherapy, Brief/ or Socioenvironmental Therapy/

1 and 11

## Cochrane Database of Systematic Reviews & Database of Abstracts of Reviews of Effects: Search Date Through August 28, 2012

“Hepatitis C” OR Hepacivirus OR HCV (Title, Abstract, Keyword)

Limit to reviews, published 2002–2012

## SCOPUS: Search Date Through August 28, 2012

TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)

(TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telaprevir))

TITLE-ABS-KEY(cohort* OR “meta analysis” OR “randomized controlled trial*” OR “systematic review*” OR “controlled clinical trial*” OR “placebo” OR “clinical trial*” OR randomized OR randomly)

(TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR “meta analysis” OR “randomized controlled trial*” OR “systematic review*” OR “controlled clinical trial*” OR “placebo” OR “clinical trial*” OR randomized OR randomly))

(TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR “meta analysis” OR “randomized controlled trial*” OR “systematic review*” OR “controlled clinical trial*” OR “placebo” OR “clinical trial*” OR randomized OR randomly))

(TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR “meta analysis” OR “randomized controlled trial*” OR “systematic review*” OR “controlled clinical trial*” OR “placebo” OR “clinical trial*” OR randomized OR randomly)) AND (LIMIT-TO(PUBYEAR, 2012) OR (LIMIT-TO(PUBYEAR, 2011) OR LIMIT-TO(PUBYEAR, 2010) OR LIMIT-TO(PUBYEAR, 2009) OR LIMIT-TO(PUBYEAR, 2008) OR LIMIT-TO(PUBYEAR, 2007) OR LIMIT-TO(PUBYEAR, 2006) OR LIMIT-TO(PUBYEAR, 2005) OR LIMIT-TO(PUBYEAR, 2004) OR LIMIT-TO(PUBYEAR, 2003) OR LIMIT-TO(PUBYEAR, 2002))

TITLE-ABS-KEY(unsafe OR safety OR harm* OR complication* OR poison* OR risk* OR side-effect* OR “side effect*” OR “undesirable effect* OR “treatment emergent” OR tolerab* OR toxic* OR “adverse effect*” OR “adverse reaction*” OR “adverse event*” OR “adverse outcome*”)

(TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR “meta analysis” OR “randomized controlled trial*” OR “systematic review*” OR “controlled clinical trial*” OR “placebo” OR “clinical trial*” OR randomized OR randomly)) AND (TITLE-ABS-KEY(unsafe OR safety OR harm* OR complication* OR poison* OR risk* OR side-effect* OR “side effect*” OR “undesirable effect* OR “treatment emergent” OR tolerab* OR toxic* OR “adverse effect*” OR “adverse reaction*” OR “adverse event*” OR “adverse outcome*”))

(TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND ((TITLE-ABS-KEY(“antiviral agent*” OR interferon* OR interferon-alpha OR “interferon alfa-2a” OR “interferon alpha-2b” OR ifnalpha2a OR ifnalpha2b OR “interferon alpha 2a” OR “interferon alpha 2b” OR “polyethylene glycols” OR pegasys OR peg-intron) OR TITLE-ABS-KEY(“peginterferon alpha-2a” OR “peginterferon alpha-2b” OR “peginterferon alpha 2a” OR “peginterferon alpha 2b” OR “pegylated interferon*” OR ifn* OR peg ifn* OR ribavirin OR rbv OR “protease inhibitor*” OR “polymerase inhibitor*” OR “hcv protease*” OR telapr))) AND (TITLE-ABS-KEY(cohort* OR “meta analysis” OR “randomized controlled trial*” OR “systematic review*” OR “controlled clinical trial*” OR “placebo” OR “clinical trial*” OR randomized OR randomly)) AND (TITLE-ABS-KEY(unsafe OR safety OR harm* OR complication* OR poison* OR risk* OR side-effect* OR “side effect*” OR “undesirable effect* OR “treatment emergent” OR tolerab* OR toxic* OR “adverse effect*” OR “adverse reaction*” OR “adverse event*” OR “adverse outcome*”)) AND (LIMIT-TO (LIMIT-TO(PUBYEAR, 2012) OR (PUBYEAR, 2011) OR LIMIT-TO(PUBYEAR, 2010) OR LIMIT-TO(PUBYEAR, 2009) OR LIMIT-TO(PUBYEAR, 2008) OR LIMIT-TO(PUBYEAR, 2007) OR LIMIT-TO(PUBYEAR, 2006) OR LIMIT-TO(PUBYEAR, 2005) OR LIMIT-TO(PUBYEAR, 2004) OR LIMIT-TO(PUBYEAR, 2003))

TITLE-ABS-KEY(counseling OR “health education” OR “patient education” OR psychotherapy OR “behavior therapy” OR “cognitive therapy” OR immuniz* OR immunotherapy OR “socioenvironmental therapy” OR “cognitive behavior* therapy” OR vaccine*)

(TITLE-ABS-KEY(“hepatitis c” OR hepacivirus OR hcv)) AND (TITLE-ABS-KEY(cohort* OR “meta analysis” OR “randomized controlled trial*” OR “systematic review*” OR “controlled clinical trial*” OR “placebo” OR “clinical trial*” OR randomized OR randomly)) AND (TITLE-ABS-KEY(counseling OR “health education” OR “patient education” OR psychotherapy OR “behavior therapy” OR “cognitive therapy” OR immuniz* OR immunotherapy OR “socioenvironmental therapy” OR “cognitive behavior* therapy” OR vaccine*))

## Ovid PsychINFO: Search Date Through August 28, 2012

hepatitis/ or (Hepatitis C or hepacivirus$ or HCV).mp.

[exp treatment/ or exp intervention/ or exp psychotherapy/ or exp alcohol rehabilitation/ or exp counseling/ or exp support groups/ or exp rehabilitation/ or exp mental health services/ or exp community services/ or exp outreach programs/ or exp drug rehabilitation/ or exp sobriety/ or exp detoxification/ or exp drug rehabilitation/ or exp treatment outcomes/ or exp alcoholics anonymous/]

alcohol*.mp.

1 and 2 and 3