# Final Prioritization Survey

This appendix displays the final prioritization survey. This survey was produced in SurveyMonkey, a web-based program. The survey poses only two questions, asking for the stakeholders name and then asking the stakeholder to give each of twelve research gaps (identified as higher priority through the first survey) a ranking of '1' through '12,' with '1' signifying the highest priority and '12' signifying the lowest priority, and to consider the Effective Health Care's Program Selection Criteria, which includes appropriateness, importance, desirability of new research/duplication, feasibility, and potential impact when making prioritization decisions. The research gaps to rank included: -Lack of studies in screen detected patients; -Lack of studies enrolling broader spectrum of patients, including those with medical and psychological comorbidities seen in clinical practice, such as advanced cirrhosis and IV drug users; -Lack of studies that adequately control for potential confounders reporting clinical outcomes in patients who experience SVR with those who do not experience SVR; -Need for well-designed, independently funded studies. Almost all of the randomized trials were funded by pharmaceutical companies. Such studies tend to report more favorable results from drugs produced by the funder than studies funded by governmental or other sources; -Lack of studies enrolling patients with advanced age (>65-70 years); -Lack of studies reporting long-term followup of patients exposed to telaprevir and boceprevir to understand the long-term harms associated with use of telaprevir and boceprevir; -Need for evidence on new drugs currently in clinical phases, including oral regimens without interferon; -Need for methodologically rigorous studies conducted in settings applicable to U.S. populations evaluating the association between achieving an SVR and improvements in clinical outcomes; -Lack of studies evaluating the usefulness of genomics and other methods for individualized treatment decisions in patients with HCV infection using genomics or other methods (e.g., treatment algorithms) and how these treatment decisions affect clinical outcomes; -Need for studies designed using an effectiveness paradigm to understand real-world effects of antiviral regimens, including effects related to the poorer treatment adherence than expected from efficacy trials; -Lack of studies assessing important long-term clinical outcomes associated with current antiviral treatments for chronic HCV infection; -Lack of studies on effects of using non-invasive methods for assessing liver fibrosis to guide treatment decisions