# Initial Prioritization Survey

This appendix displays the initial prioritization survey. The survey was produced in SurveyMonkey, a web-based survey program. The survey poses 19 questions, beginning with asking the stakeholders to identify their perspective (as a clinician, researcher, research funder, policymaker, payer, and/or consumer advocate), provide demographic information (including name, degrees, address, e-mail address, and phone number), and an open-ended question asking what the stakeholder or members of their stakeholder group would most like to know about treatment for hepatitis C. Following these introductory questions, the stakeholders were asked to rate the evidence gaps as ‘High’, ‘Medium,’ or ‘Low’ priority, provide feedback on each rating, and were also given an opportunity to suggest additional research gaps. For populations, the research gaps included: -Lack of studies enrolling a broader spectrum of patients such as those with medical and psychological comorbidities seen in cirrhosis and IV drug users -Lack of studies enrolling patients with advanced age (>65–70 years) -Lack of studies of treatment in screen-detected patients -Need for methodologically rigorous studies conducted in settings applicable to U.S. populations evaluated valuating the association between achieving a SVR and improvements in clinical outcomes For interventions, the research gaps included: -Need for additional trials evaluating the boceprevir regimen by the FDA in antiviral-naïve patients without baseline cirrhosis, to verify that results from studies of previously treated patients were appropriately generalized -Lack of studies evaluating the usefulness of genomics and other methods for individualizing treatment decisions in patients with HCV infection using genomics or other methods (e.g. treatment algorithms) and how these treatment decisions affect clinical outcomes -Need for evidence on new drugs currently in clinical trial phases, including oral regimens without interferon -Lack of studies on effects of using non-invasive methods for assessing liver fibrosis to guide treatment decision For comparators, the research gaps included: -Lack of head-to-head studies comparing triple therapy regimens (telaprevir or boceprevir + pegylated interferon + ribavirin) with a protease inhibitor in subgroups defined by age, body weight, baseline fibrosis stage, and other important factors -Lack of studies that adequately control for potential confounders reporting clinical outcomes in patients who experience SVR with those who do not experience SVR For outcomes and timing. the research gaps included: -Lack of studies assessing important long-term clinical outcomes associated with current antiviral treatments for chronic HCV infection -Need for well-conducted studies on the effects of achieving a SVR on long-term quality of life -Lack of studies reporting long-term followup of patients exposed to telaprevir and boceprevir to understand the long-term harms associated with use of telaprevir and boceprevir For study designs, the research gaps included: -Need for studies designed using an effectiveness paradigm to understand real-world effects of antiviral regimens, including effects related to the poorer treatment adherence than expected from efficacy trials -Need for well-designed, independently-funded studies. Almost all of the randomized trials were funded by pharmaceutical companies. Such studies tend to report more favorable results for drugs produced by the funder than studies funded by governmental or other sources