# Acronyms

AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
EHC: Effective Health Care
EPC: Evidence-based Practice Center
FDA: U.S. Food and Drug Administration
HCV: Hepatitis C virus
PICOT: Population, Intervention, Comparator, Outcome, Timing
RCT: Randomized Controlled Trial
RR: Relative risk
SVR: Sustained virologic response
U.S.: United States