# Results

## Stakeholders

The stakeholders broadly represented clinical, research and advocacy perspectives on gastroparesis and constipation. The panel comprised nine stakeholders, including a patient advocate and non-motility specialist statistician. We generated lists of potential stakeholders via a review of Technical Expert Panel members from the systematic review, and added several new members to our team of stakeholders who did not have any corporate interest in the development of WMC. Six of nine stakeholders are considered clinical experts in gastrointestinal motility and neurogastroenterological disorders, one is a general expert in gastroenterology who designs clinical trials, and the remaining two members offered a public perspective and research methodology background which were very useful.

## Knowledge Gaps

Using the information from the Johns Hopkins University EPC draft systematic review, Wireless Motility Capsule versus Other Diagnostic Technologies for Evaluating Gastroparesis and Constipation, a series of key areas of unanswered questions or gaps in knowledge was identified by the FRN team from the areas with low or insufficient strength of evidence noted in the systematic review. We sought to represent all these evidence gaps with the design of a series of questions for prioritization.

A lack of basic and fundamental knowledge about WMC measurements for both normal patients and those with suspected or real motility disorders, as well as a lack of basic and fundamental knowledge about the comparison tests of scintigraphy, manometry, and ROMs affected the strength of evidence. For example, what is the range of values for measurements with the WMC in both normal patients, those suspected of motility disorders, and those with actual motility disorders? Many of these values have yet to be firmly established, and thus the FRN team felt that some of these foundational natural history, epidemiology and methodological gaps would help lay the framework needed for more systematic research and discovery into the clinical, topical questions. Therefore, in analyzing the evidence gaps, the FRN team identified two types of gaps: (1) clinical topical gaps and (2) foundational epidemiology gaps, which we refer to as methodological gaps. Because of the distinct nature of these two types of gaps, and consistent with AHRQ guidance, (www.effectivehealthcare.ahrq.gov/ehc/products/378/1039/MFRN9_PresentationofFutureResearchNeeds_FinalReport_20120418.pdf) these two types of gaps were prioritized separately by the stakeholder panel. See Tables 2 and 3 for complete lists of clinical and methodological gaps.

Table 2 Wireless motility capsule stakeholder prioritized clinical knowledge gaps

Clinical Knowledge Gaps | Priority Rank^1^ (1 = Highest Priority)
Top Tier
1. Comparative effectiveness of managing with WMC (gastric dysmotility/gastroparesis) | 1
2. Comparative diagnostic accuracy and safety (gastric dysmotility/gastroparesis) | 2
3. Gold standard (gastric dysmotility/gastroparesis) | 3
4. Comparison of WMC and scintigraphy results (gastroparesis) | 4
5. Gold standard (colonic dysmotility/slow-transit constipation) | 5
6. Reproducibility of WMC results (gastroparesis) | 5
7. Comparative diagnostic accuracy and safety (colonic dysmotility/slow-transit constipation) | 6
8. Incremental diagnostic accuracy (gastric dysmotility/gastroparesis) | 7
9. Incremental diagnostic accuracy (colonic dysmotility/slow-transit constipation) | 8
Other Gaps
10. Distinction of subtypes of gastroparesis (gastric dysmotility/gastroparesis) | 9
11. Best test or combination for predicting outcomes after colectomy (colonic dysmotility/slow-transit constipation) | 9
12. Comparative accuracy in predicting response to treatment (colonic dysmotility/slow-transit constipation) | 9
13. Utility of colonic pressure (colonic dysmotility) | 10
14. Differentiating IBS-C from idiopathic constipation (colonic dysmotility/slow-transit constipation) | 10
15. Comparisons of WMC pressure profiles (gastroparesis) | 10
16. Best test or combination for predicting outcomes without colectomy (colonic dysmotility/slow-transit constipation) | 11
17. Comparative accuracy in predicting response to treatment (gastric dysmotility/gastroparesis) | 12
18. Comparative value in monitoring response to treatment (gastric dysmotility/gastroparesis) | 13
19. Comparative value in monitoring response to treatment (colonic dysmotility/slow-transit constipation) | 13
20. Colonic pressure patterns after waking (colonic dysmotility) | 13
21. Evaluation of high-amplitude contractions (colonic dysmotility) | 13

C = clinical knowledge gap; WMC = wireless motility capsule

It was possible for multiple gaps to have the same priority rank if the summation scores for computing the ranks were the same (Appendix C).

Table 3 Wireless motility capsule stakeholder prioritized methodological knowledge gaps

Methodological Knowledge Gaps | Priority Rank (1 = Highest Priority)
Top Tier
1. WMC data in patients with gastric and colonic dysmotility | 1
2. WMC data in nondiseased populations | 2
3. Rates of test failures and need for additional tests | 3
4. WMC diagnostic accuracy and safety in gastroparesis subtypes | 4
5. Thresholds | 5
6. Correlation between WMC values and histopathology | 6
Other Gaps
7. Colonic pressure patterns following meal ingestion. | 7
8. Relation of baseline WMC values with long-term followup values | 8
9. WMC data compared with other tests in non-diseased populations | 9
10. Concurrent tests | 10
11. Masking interpreters of WMC data | 11
12. Use of historical controls in WMC research | 12

M = methodological knowledge gap; WMC = wireless motility capsule

The gap topics were reviewed by the stakeholder panel in two lists to allow them to comment, suggest and rank important issues for both the directly important clinical issues for WMC and the methodological questions. We received suggestions for additional research questions, which were solicited at the first round of survey, and then subject to general review at the second round of questions. Our stakeholder panel readily identified these areas as necessary and important during both rounds of feedback and specifically they focused on certain questions of greater importance and priority.

The highest ranked clinical evidence gap reflected the uncertainty in the role of WMC in outcomes for patients with presumed gastroparesis and the role of WMC as a replacement test versus adjunct test for diagnosis. Consensus guidelines suggest that WMC is a replacement test for current testing methods, however additional research would lend more weight to that argument. It is currently very difficult in active practice to get access to the WMC for some patients due to lack of insurance coverage. But further evidence of benefit may facilitate wider access to the WMC. This is clearly a high priority. The other top-ranked question asked whether these same patients with suspected gastroparesis would have comparable results from scintigraphy, antroduodenal manometry, plain x ray after marker blind capsule ingestion, endoscopy, or combination of tests in diagnosis of gastroparesis. Similarly the next ranked gaps addressed the question of which test should serve as the gold standard or reference standard for comparison, and whether a confirmatory test is required after use of WMC. Reproducibility of the WMC was also thought to be important and ties into the previous questions which tried to establish the role of WMC in testing. Beyond these knowledge gaps on gastroparesis the next set of questions addressed slow-transit constipation, including establishing the role of WMC in diagnosis compared with other standard tests for ability to diagnose, as well as accuracy and safety in diagnosis.

The next series of gaps focused on the incremental value of WMC in addition to other testing methods for gastric emptying delay and slow-transit constipation. Interestingly, there were also ranked questions in the top tier asking about correlating pathology with clinical history and WMC findings. This echoes the questions from the methodological side asking about the same correlation. Also a focus was the role of WMC in colonic dysmotility to predict outcomes, or to predict the effects medical and/or surgical therapy on outcomes.

The most highly ranked methodological gaps (Table 3) made clear the basic data ranges for WMC in patients have yet to be firmly established in non-diseased populations and those with suspected gastric or colonic dysmotility. With better established norms for diseased and non-diseased patients there can be better framing of future questions and research endeavors. The next most highly ranked gaps were very similar to the initial research questions asked by the original systematic review, which had only low strength of evidence. With additional quality research, the panel thought that the strengths and weaknesses of WMC would be made more apparent. Thus, they suggested a priority area for research would be future studies that focus on establishing the role of WMC comparatively with scintigraphy, manometry, and ROMs as well as to find out information about test failure and need for additional tests. It was also considered important to assess diagnostic accuracy of the test when used by nonacademic specialists or as a front-line test. Other priority items included establishing the thresholds of diagnostic accuracy and establishing the basic science connection between WMC results and histopathological findings from patients with known disease, if one exists. All of these basic foundational or methodological questions were ranked highly by participants in both rounds. These are by definition high-priority areas for future research.

## Future Research Needs and Study Design Considerations

We next developed a list of research questions based on the FRN, (i.e., top tier of prioritized evidence gaps) with sufficient detail for use by researchers and funders (i.e., research questions, PICOTS information and considerations of pros and cons of various research designs). Our FRN focused on broader topics for review by stakeholders, which are summarized in Table 4. Our FRN team has recommended study design characteristics based on the previous systematic review and feedback from the stakeholders.

Table 4 Summary of research needs (top tier)

Gap | Question | Population | Intervention | Comparator | Outcomes | Timing^a^ | Setting | Potential Study Designs
Clinical Questions
1. Comparative effectiveness of managing with WMC (gastric dysmotility/gastroparesis) | Among patients with [underlined: presumed gastroparesis], how do clinical outcomes differ between patients managed with WMC data alone versus those managed with scintigraphy data alone? | Presumed gastroparesis | WMC alone | 4 hour gastric scintigraphy by standard protocol (ANMS consensus) | Clinical outcomes – diagnostic accuracy, harms, motility assessment, tolerability, treatment decisions, patient centered outcomes – symptom improvement, quality of life resource utilization | Simultaneous | Academic, multi-center practice | Randomized, controlled trial, prospective
2. Comparative diagnostic accuracy and safety (gastric dysmotility/gastroparesis) | Among patients with [underlined: suspected gastroparesis], how does the WMC compare with gastric scintigraphy, antroduodenal manometry, and endoscopy in its accuracy and safety in diagnosing gastroparesis? | Suspected gastroparesis | WMC alone | 4 hour gastric scintigraphy by standard protocol (ANMS consensus), or antroduodenal manometry and/or endoscopy | Clinical outcomes – diagnostic accuracy, harms, motility assessment, tolerability, treatment decisions, patient centered outcomes – symptom improvement, quality of life resource utilization | | Academic, multi-center practice | Randomized, controlled trial, prospective
3. Gold standard (gastric dysmotility/gastroparesis) | What is an appropriate test (gold standard) to compare with WMC in the diagnosis and monitoring of patients with [underlined: gastroparesis]? (e.g., clinical diagnosis, 4-hour gastric scintigraphy, antroduodenal manometry, endoscopy, plain X-ray of the abdomen 5 hours after swallowing a “dumb” radiopaque pill, a combination of tests) | Suspected or known gastroparesis subjects | WMC alone | Clinical history, standardized GI questionnaire, 4 hour gastric emptying, antroduodenal manometry, endoscopy, plain x ray 5 hours after swallowing a patency capsule, or some combination above | Clinical outcomes – diagnostic accuracy, harms, motility assessment, tolerability, treatment decisions, patient centered outcomes – symptom improvement, quality of life resource utilization | | Academic, multicenter practice | Randomized controlled prospective trial, or prospectively enrolled but retrospectively reviewed cases, blinded interpretation of results
4. Comparison of WMC and scintigraphy results (gastroparesis) | In the clinical evaluation of patients with suspected gastroparesis, do abnormal WMC gastric emptying times correlate with 4-hour gastric scintigraphy results well enough to replace scintigraphy, or is a confirmatory scintigraphy required after an abnormal WMC test? | Suspected gastroparesis | WMC alone | 4 hour gastric scintigraphy or WMC plus gastric scintigraphy | Clinical outcomes – diagnostic accuracy, harms, motility assessment, tolerability, treatment decisions, patient centered outcomes – symptom improvement, quality of life resource utilization | | Academic multicenter practice | Randomized controlled prospective trial, not device funded, blinded interpretation of results
5. Gold standard (colonic dysmotility/slow-transit constipation) | What is an appropriate test (gold standard) to compare with WMC in the diagnosis and monitoring of patients with slow-transit constipation? (e.g., clinical diagnosis, colonic scintigraphy, radiopaque markers, a combination of tests) | Suspected Slow transit constipation | WMC alone | Clinical history, GI questionnaire, colonic scintigraphy, radiopaque markers, combinations of tests | Clinical outcomes – diagnostic accuracy, diagnostic gain with additional tests, safety, tolerability | | Academic practice with scintigraphy available – caveat that scintigraphy is very expensive and this study may be prohibitively expensive | Randomized controlled prospective, blinded interpretation of results
6. Reproducibility of WMC results (gastroparesis) | In normal patients and those with gastroparesis, how reproducible are WMC studies performed 2 weeks apart? | Normal and suspected gastroparesis | WMC | Repeat WMC at later time | Reproducibility of test results, change in specificity or sensitivity with two tests as compared with one | | Any, preferably academic | Prospective, Blinded review, all patients receive same intervention.
7. Comparative diagnostic accuracy and safety (colonic dysmotility/slow-transit constipation) | Among patients with suspected slow-transit constipation how does the WMC compare with radiopaque markers and scintigraphy in accuracy in diagnosis and safety? | Suspected Slow transit constipation | WMC | Radiopaque markers, colonic scintigraphy | Accuracy, Safety | | Any | Prospective, blinded interpretation, followed at 1 and 30 days for harms
8. Incremental diagnostic accuracy (gastric dysmotility/gastroparesis) | What is the incremental value of WMC in addition to gastric scintigraphy, antroduodenal manometry or endoscopy to diagnose delayed gastric emptying or dysmotility? | Suspected gastric emptying delay | WMC | Gastric scintigraphy, antroduodenal manometry, endoscopy | Incremental value in diagnosis | | Any | Blinded review of results, controlled trial, could examine cohorts
9. Best test or combination for predicting outcomes after colectomy (colonic dysmotility/slow-transit constipation) | Among patients with confirmed colonic dysmotility who undergo colectomy, is WMC data alone, or scintigraphy plus radiopaque markers, or the combination of all three the best predictor of whole gut dysmotility and clinical outcomes? | Confirmed colonic dysmotility patients who post test(s) have undergone or not undergone colectomy | WMC | Scinti-graphy, radiopaque markers, combination of all three | Clinical outcomes – diagnostic accuracy, harms, motility assessment, tolerability, treatment decisions, patient centered outcomes – symptom improvement, quality of life resource utilization | | Any | Retrospective with prospectively collected data.
Methodological Questions
1. WMC data in patients with gastric and colonic dysmotility | Among patients with gastric and colonic dysmotility, what are the ranges of WMC values for temperature, pH, pressure pattern and transit time in the stomach, intestines and colon? | Suspected gastric and suspected colonic dysmotility | WMC | Ranges of normal, no comparators needed | Temperature, pH, pressure patterns, transit time | | Any | Prospective enrolled, blinded review, with confirmatory second reviewer to calculate kappa
2. WMC data in non-diseased populations | In non-diseased populations, what are the distributions of age-, race- and sex-specific values for pressure patterns/amplitude/frequency, temperature, pH, and transit time in the stomach, intestines and colon, as measured by the WMC? | Healthy patients, multiple ages, all sexes | WMC | Ranges of normal, comparators would be in patients of different ages and sexes | Temperature, ph, pressure patterns, transit time | | Any | Prospective enrolled, blinded review
3. Rates of test failures and need for additional tests | How does the WMC compare with scintigraphy, manometry and radiopaque markers in the rates of test failures and need for additional tests? | Suspected gut dysmotility patients | WMC | Scintigraphy, manometry, radiopaque markers | Diagnostic accuracy, Test failure, need for additional tests | | Any | Randomized, prospective, also could collect data prospectively and retrospectively analyze as ultimate outcome becomes available
4. WMC diagnostic accuracy and safety in gastroparesis subtypes | How do the diagnostic accuracy, safety and resource utilization of the WMC differ when used in ambulatory gastroenterology clinics and primary care offices - and when the WMC results are interpreted by primary gastroenterologists, primary care physicians or nurse practitioners? | Ambulatory general gastroenterology patients and primary care physicians offices, suspected motility disorder with symptoms of gastric emptying delay or colonic transit abnormality | WMC | Clinical diagnosis | Diagnostic accuracy, safety, resource utilization | | Ambulatory gastroenterology practice and primary care offices | Prospective trial, observation in practice due to concerns over difficulties with randomizing at multiple local physicians offices.
5. Thresholds | What thresholds should be used to differentiate diagnostic accuracy between the WMC and another test? (e.g., sensitivity, specificity, % agreement, other) | Any populations, healthy vs. diseased | WMC | Other testing modalities, what threshold differentiates effectively | Threshold optimal range for determining diagnostic accuracy | | Any | Statistical analysis based on above data to determine optimal thresholds, would need data from other trials to calculate.
6. Correlation between WMC values and histopathology | Among patients with motility disorders, are WMC values correlated with the histopathological findings from full-thickness or standard biopsy? | Gastric or colonic dysmotility or general gut dysmotility patients | WMC | Histopathology samples or genetic samples from patients with known disease | Clinical outcomes – diagnostic accuracy, harms, motility assessment, tolerability, treatment decisions, patient centered outcomes – symptom improvement, quality of life resource utilization | | Academic center, with experience in genetics and tissue banking also neurogastro staining techniques | Prospectively collected registry information that can be correlated with ongoing genetic and advanced neurogastroenterological pathology diagnostic techniques as they become available

ANMS = American Neurogastroenterology and Motility Society; GI = gastrointestinal; WMC = wireless motility capsule

a Timing field left blank if there were no salient timing issues.

### Study Design Considerations

Clinical research questions (Table 4) were framed to be relevant to clinical providers. The stakeholders offered general guidance towards better study design. Many stakeholders remarked that prospective trials would be ideal to help resolve some of the methodological issues. Other stakeholders wanted simultaneous assessment of controls and suspected cases within the same study undergoing analysis, which is standard diagnostic test methodology. There were some concerns about how expensive or non-feasible a particular project may be. This was true for all the longitudinal projects suggested within the questions. There were significant concerns expressed about using colonic scintigraphy, because as a modality it is only available in two centers and it is very difficult to complete as well as expensive and taxing on the patients. There were also concerns about the expense of tandem test study designs, where multiple testing modalities were to be performed on the same patient. Few stakeholders suggested that further comparative effectiveness trials were the only area of research need, since there were so many methodological issues which also need attention.

From the original systematic review, several areas of focus on methodological quality were apparent, and the comments of the stakeholders for the FRN project echoed these same concerns. Testing modalities should have standardized protocols so that they can be compared between studies (Table 5). For instance, prior to WMC, proton pump inhibitors should ideally be held for 7 days. The test should be performed using the WMC ingested at appropriate times as per manufacturer's instructions. For gastric emptying study performance to be optimal and reproducible, the patients should have controlled blood sugar at the time of testing, should not have smoked cigarettes within 24 hours, and should be off all prokinetics for 7 days prior to testing. Studies that are performing these tests as part of clinical research should collect data about whether or not testing was carried out to the conventional standards recommended by the American Neurogastroenterology and Motility Society. In an ideal world, all tested motility patients should have been weaned off all narcotics prior to any motility testing, as narcotics directly influence bowel transit. Some of these requirements are difficult to achieve in real life patients, many of whom have longstanding poor diabetes control or narcotic dependence. But in the ideal research setting close attention should be paid to these details.

Table 5 Test Protocols for the diagnosis of gastroparesis and slow-transit constipation

Test | Duration of Test | Timing of Meal or X Ray | Prespecified Criteria for Inclusion
Gastric scintigraphy | 4 hour testing | Prespecified meal with radiolabeled egg | Off tobacco, off narcotics, off prokinetics, glucose controlled below 250, off antidepressants or stable for 6 months
WMC | As per protocol | Prespecified timing of meal Smartbar vs. Eggbeaters | Off tobacco, Off prokinetics, Off proton pump inhibitor,
Colon transit testing | As per protocol, prespecify which protocol and timing of ingestion | Prespecify x-ray timing to document stool passage, or lack thereof | Off prokinetics, Off laxatives, Stable antidepressants

WMC = wireless motility capsule

There was overlap among the questions, and some of the same research questions could be answered within the same study design if performed on appropriate populations, and with appropriate intervention comparisons (Table 6). We elected to keep a greater number of questions and focus on better study design for these types of studies.

Table 6 Major clinical and methodological questions were within same few categories

Categories of Clinical Questions | Categories of Methodological Questions
- Comparative diagnostic accuracy and safety of gastric and colonic dysmotility testing; - Establishing a gold standard for gastric dysmotility; - Comparison of WMC testing and scintigraphy; - Establishing a gold standard for colonic dysmotility; - Reproducibility of WMC testing for gastroparesis; - Incremental diagnostic accuracy for both gastric and colonic dysmotility; - Distinction of subtypes of gastroparesis and determining the best test or combination for predicting outcomes after colectomy for colonic dysmotility; - Comparative accuracy in predicting response to treatment for colonic dysmotility | - WMC test data in patients with gastric and colonic dysmotility and non-diseased populations; - Rates of test failures and need for additional tests; - WMC diagnostic accuracy and safety in gastroparesis subtypes; - Thresholds of analysis and correlation between WMC test values and histopathology

WMC = wireless motility capsule

## Ongoing Research

We scanned the literature for any ongoing clinical trials which may have already addressed these high-priority areas. We found two clinical trials.gov references which had already published the results on populations outside of the scope of our review, spinal cord injury patients and critically ill intensive care patients. One clinicaltrials.gov reference was not assessing the role of WMC in diagnosis of constipation or gastroparesis, but instead focused on acid measurement. We also identified a funded research protocol which likely has yet to complete enrollment regarding effect of medication for constipation on outcomes with WMC. We await the outcome of this trial, but it is only representative of one of many treatment modalities available to these patients. No other identified research projects were identified which had already answered the questions we designed.