# References

10 Hasler WL. Gastroparesis: pathogenesis, diagnosis and management. Nat Rev Gastroenterol Hepatol. 2011;8(8):438-53. [pmid: 21769117].
11 Camilleri M, Bharucha AE, Farrugia G. Epidemiology, mechanisms, and management of diabetic gastroparesis. Clin Gastroenterol Hepatol. 2011;9(1):5-12. quiz e7. [pmid: 20951838].
12 Wang YR, Fisher RS, Parkman HP. Gastroparesis-related hospitalizations in the United States: trends, characteristics, and outcomes, 1995-2004. Am J Gastroenterol. 2008;103(2):313-22. [pmid: 18047541].
13 Rao SS, Kuo B, McCallum RW, et al. Investigation of colonic and whole-gut transit with wireless motility capsule and radiopaque markers in constipation. Clin Gastroenterol Hepatol. 2009;7(5):537-44. [pmid: 19418602].
14 Stewart WF, Liberman JN, Sandler RS, et al. Epidemiology of constipation (EPOC) study in the United States: relation of clinical subtypes to sociodemographic features. Am J Gastroenterol. Dec. 1999;94(12):3530-40. [pmid: 10606315].
15 Suares NC, Ford AC. Prevalence of, and risk factors for, chronic idiopathic constipation in the community: systematic review and meta-analysis. Am J Gastroenterol. Sep. 2011;106(9):1582-91. quiz 1, 92. [pmid: 21606976].
16 Ribas Y, Saldana E, Marti-Rague J, et al. Prevalence and pathophysiology of functional constipation among women in Catalonia, Spain. Dis Colon Rectum. Dec. 2011;54(12):1560-9. [pmid: 22067186].
17 Rao SS, Ozturk R, Laine L. Clinical utility of diagnostic tests for constipation in adults: a systematic review. Am J Gastroenterol. 2005;100(7):1605-15. [pmid: 15984989].
18 Brandt LJ, Prather CM, Quigley EM, et al. Systematic review on the management of chronic constipation in North America. Am J Gastroenterol. Suppl 1. 2005;100:S5-S21. [pmid: 16008641].
19 Tack J, Muller-Lissner S, Stanghellini V, et al. Diagnosis and treatment of chronic constipation--a European perspective. Neurogastroenterol Motil. 2011;23(8):697-710. [pmid: 21605282].
20 Carey T, Sanders GD, Viswanathan M, Trikalinos TA, Kato E, Chang S. Framework for Considering Study Designs for Future Research Needs. Methods Future Research Needs Paper No. 8. (Prepared by the RTI –UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.