# Executive Summary

## Background

### Gastroparesis

Gastroparesis delays gastric emptying without a physical blockage.1 Its symptoms are nausea, vomiting, early satiety, bloating, abdominal pain, and postprandial fullness.2 Its prevalence is estimated to be 9.6 per 100,000 among men and 37.8 per 100,000 among women.2 Between 1.5 and 3 million Americans are affected. Related hospitalizations increased by 158 percent between 1995 and 2004.^3^ Evaluation may employ gastric emptying scintigraphy, antroduodenal manometry, and the wireless motility capsule (WMC) – and it guides nutritional, medical, and surgical therapies.

### Constipation

Constipation is common, occurring in 15 to 20 percent of the population.4-6 It is defined as fewer than two bowel movements per week, or a decrease in a person's normal frequency accompanied by straining, difficulty defecating, or passage of hard stools.4 Patients with slow-transit constipation often have severe symptoms, with prolonged intervals between bowel movements, and may be refractory to standard therapies. Prevalence of slow-transit constipation is 0.03–0.17 percent.7 For patients with refractory symptoms, colonic physiology testing may include radiopaque markers (ROM), colonic scintigraphy, manometry, and the WMC.8,9

### Objectives of the Systematic Review

The WMC is a new modality for diagnosing gastric and colonic motility disorders. The Johns Hopkins Evidence-based Practice Center recently completed an Agency for Healthcare Research and Quality (AHRQ)-funded systematic review of the effectiveness of WMC compared with other tests of gastric and colonic motility (see analytic framework, Figure A). We also sought to define populations that would benefit most from motility testing.

Figure A Analytic framework of the comparative effectiveness of diagnostic technologies for evaluating gastroparesis and constipation

KQ = Key Question

The diagram shows the relationship of the Key Questions to populations, interventions, and outcome measures. Adults with suspected gastroparesis receive the wireless motility capsule (WMC) alone (KQ1) or in combination with other tests (KQ2) and the diagnostic results are compared to results for scintigraphy, antroduodenal manometry, or endoscopy. Outcome measures are motility assessment (transit time, pressure patterns), diagnostic accuracy (gastroparesis), treatment decisions (change in medications, change in nutrition, surgery, referral), patient-centered outcomes (symptom improvement, quality of life, patient satisfaction), harms (capsule retention, radiation exposure, mortality), resource utilization (test failure – unable to read results, need for additional tests, use of other health care services – hospitalizations, physician visits). Adults with suspected slow-transit constipation receive the wireless motility capsule (WMC) alone (KQ3) or in combination with other tests (KQ4) and the diagnostic results are compared to results for scintigraphy or radiopaque markers. Outcome measures are the same as above, except that the measure for diagnostic accuracy is slow-transit constipation.

In the systematic review of this topic, we formulated Key Questions (KQ), reviewed the literature extensively, and obtained feedback from experts. The results are summarized in Table A.

Table A Summary of the results from the systematic review on the wireless motility capsule

Topic and Key Questions | Key Findings | Strength of Evidence
Comparative diagnostic accuracy of WMC for gastroparesis. KQ 1: In the evaluation of gastric dysmotility, how does the WMC alone compare with gastric scintigraphy, antroduodenal manometry, and endoscopy in terms of diagnostic accuracy of gastric emptying delay, motility assessment, treatment decisions, patient-centered outcomes, harms, and resource utilization? | Seven studies evaluated diagnosis of gastric emptying delay. We found low strength of evidence that WMC alone was comparable to scintigraphy for diagnostic accuracy, motility assessment, treatment decisions, and resource utilization. | Low
Incremental diagnostic accuracy for WMC in combination with other diagnostic methods for gastroparesis. KQ 2: When gastric scintigraphy, antroduodenal manometry, or endoscopy is used in the evaluation of gastric dysmotility, what is the incremental value of also using the WMC in terms of diagnostic accuracy of gastric emptying delay, motility assessment, treatment decisions, patient-centered outcomes, harms, and resource utilization? | We found two studies evaluating WMC as an add-on to other testing. The strength of evidence was low for diagnostic accuracy and motility assessment of WMC in combination with other modalities. The addition of WMC increased diagnostic yield. | Low
Comparative diagnostic accuracy of WMC for slow-transit constipation. KQ 3: In the evaluation of colonic dysmotility, how does the WMC alone compare with radiopaque markers and scintigraphy in terms of diagnostic accuracy of slow-transit constipation, motility assessment, treatment decisions, patient-centered outcomes, harms, and resource utilization? | Nine studies analyzed colon transit disorders and provided moderate strength of evidence for diagnostic accuracy, motility assessment, and harms. WMC was comparable to radiopaque markers. Few harms were reported. The evidence was insufficient to draw conclusions about effects of WMC on treatment decisions and resource utilization. | Low
Incremental diagnostic accuracy for WMC in combination with other diagnostic methods for slow-transit constipation. KQ 4: When a radiopaque marker or scintigraphy is used in the evaluation of colonic dysmotility, what is the incremental value of also using the WMC in terms of diagnostic accuracy of slow-transit constipation, motility assessment, treatment decisions, patient-centered outcomes, harms, and resource utilization? | No studies directly assessed use of WMC in combination with other tests to detect colon transit delay. | Insufficient

KQ = Key Question; ROM = radiopaque markers; WMC = wireless motility capsule

Overall, the strength of evidence regarding the ability of WMC to detect gastroparesis or slow-transit constipation was graded as low (see KQs listing in Table A). The main limitations were inconsistencies in reporting the performance of motility testing modalities. Great variability existed in administering diagnostic tests and in assessing those tests. No uniform standards define differences in diagnostic accuracy, so we arbitrarily chose a 10 percent difference in sensitivity or specificity for reference standards, such as gastric scintigraphy, and device concordance for non-reference standards, such as ROM.

Most of the “normal” subjects upon which the tests were validated were college-age men, while most of the patients with suspected gastroparesis or constipation were women over the age of 50 years. Since the population of interest comprised motility patients, we excluded studies that included only nondiseased participants.

The major strength of the review was its comprehensiveness. We reviewed abstracts, queried industry sources for unpublished studies, and contacted study authors for missing data.

### Conclusions of the Systematic Review

WMC is comparable to other modalities in use for detecting delayed gastric emptying and slow-transit constipation. Data are insufficient to determine the optimal timing of WMC in diagnostic algorithms.

## Methods

The objectives of the Future Research Needs (FRN) project were to identify the evidence gaps highlighted by the results of the systematic review and to create a set of prioritized FRN to guide stakeholders in future decisions.

### Evidence Gap Identification

Evidence gaps were identified in the review writing process based on the strength of evidence, applicability, and limitations of the review. Individuals who contributed to review writing met multiple times and circulated by email lists of potential questions to identify gaps. This process developed a list of research gaps to be presented to the stakeholders.

### Stakeholder Engagement for Additional Gap Identification and Prioritization

#### Stakeholder Identification

Important stakeholder categories to include are patients/advocates, clinical experts, and payers. Stakeholders from these categories were identified from the Key Informants and Technical Expert Panel members who had been the most responsive for the systematic review, as well as new participants suggested by the review investigators.

#### Orienting Stakeholders

The stakeholders were provided by email a description of the project, the draft of the executive summary of the review, and a web link to the complete draft report.

#### Engagement Round 1, Gap List Review and Preliminary Prioritization

The Evidence-based Practice Center's (EPC) list of research gaps were presented to the stakeholders by email for review and for suggestions of additional gaps within the scope of the systematic review. They were instructed to carry out a preliminary prioritization of the gaps. To perform this preliminary prioritization, they were asked to choose their top 5 choices and rank them in priority from 1 (highest) to 5 based on the criteria of (1) importance (prevalence and severity of condition, lack of or inadequacy of alternatives, burden of condition to patients and healthcare system), and (2) impact (potential to change practice and/or to improve clinical and patient outcomes).

#### Engagement Round 2, Final Prioritization

The team incorporated the stakeholder comments and additional suggestions from Engagement 1 into a final list of gaps for final prioritization. This list included the preliminary ranking from the previous engagement. Each stakeholder was presented with this list and asked to choose their top 5 choices and prioritize them as described above. Stakeholders were also asked if they were aware of any ongoing studies addressing the gaps (duplication), and they were encouraged to comment on the feasibility of research addressing the gaps.

#### Top-Tier Future Research Needs

The individual priority ratings of the stakeholders were summed for each question to get global ratings that were used to sort the questions by priority. The priority ranking was inspected by the EPC team to determine if there was an obvious cutpoint between a top tier of gaps and the remainder. If the global ranking was a continuum with no apparent cutpoint, the top half of the gaps or the top 10, whichever was fewer, was chosen as the top tier and is considered the FRN.

### External Literature Searches

To identify ongoing clinical trials that may have addressed our Key Questions, we searched the World Health Organization International Clinical Trials Registry Platform (apps.who.int/trialsearch/) and clinicaltrials.gov for trials registered since the search cutoff date of the review.

## Results

### Knowledge Gaps

Using the information from the systematic review of the comparative effectiveness of WMC testing, knowledge gaps were identified in numerous areas with low strength of evidence. The reason that most strength of evidence (SOE) was low was a lack of fundamental knowledge about WMC measurements—for both normal patients and those with suspected or documented motility disorders, as well as a lack of fundamental knowledge about scintigraphy, manometry, and ROM measurements. The range of WMC values in normal patients, those suspected of motility disorders, and those with documented motility disorders is undefined. These foundational gaps may need to be addressed before clinical gaps can be addressed productively. Therefore, the EPC team identified not only clinical knowledge gaps derived directly from the Key Questions of the review (Table B), but also methodological gaps in the foundational knowledge of test results from normal and diseased patients (Table C).

Table B Wireless motility capsule stakeholder prioritized clinical knowledge gaps

Clinical Knowledge Gaps | Priority Rank^a^ (1 = Highest Priority)
Top Tier
1. Comparative effectiveness of managing with WMC (gastric dysmotility/gastroparesis) | 1
2. Comparative diagnostic accuracy and safety (gastric dysmotility/gastroparesis) | 2
3. Gold standard (gastric dysmotility/gastroparesis) | 3
4. Comparison of WMC and scintigraphy results (gastroparesis) | 4
5. Gold standard (colonic dysmotility/slow-transit constipation) | 5
6. Reproducibility of WMC results (gastroparesis) | 5
7. Comparative diagnostic accuracy and safety (colonic dysmotility/slow-transit constipation) | 6
8. Incremental diagnostic accuracy (gastric dysmotility/gastroparesis) | 7
9. Incremental diagnostic accuracy (colonic dysmotility/slow-transit constipation) | 8
Other Gaps
10. Distinction of subtypes of gastroparesis (gastric dysmotility/gastroparesis) | 9
11. Best test or combination for predicting outcomes after colectomy (colonic dysmotility/slow-transit constipation) | 9
12. Comparative accuracy in predicting response to treatment (colonic dysmotility/slow-transit constipation) | 9
13. Utility of colonic pressure (colonic dysmotility) | 10
14. Differentiating IBS-C from idiopathic constipation (colonic dysmotility/slow-transit constipation) | 10
15. Comparisons of WMC pressure profiles (gastroparesis) | 10
16. Best test or combination for predicting outcomes without colectomy (colonic dysmotility/slow-transit constipation) | 11
17. Comparative accuracy in predicting response to treatment (gastric dysmotility/gastroparesis) | 12
18. Comparative value in monitoring response to treatment (gastric dysmotility/gastroparesis) | 13
19. Comparative value in monitoring response to treatment (colonic dysmotility/slow-transit constipation) | 13
20. Colonic pressure patterns after waking (colonic dysmotility) | 13
21. Evaluation of high-amplitude contractions (colonic dysmotility) | 13

C = clinical knowledge gap; WMC = wireless motility capsule

a It was possible for multiple gaps to have the same priority rank if the summation scores for computing the ranks were the same (Appendix C).

Table C Wireless motility capsule stakeholder prioritized methodological knowledge gaps

Methodological Knowledge Gaps | Priority Rank (1 = Highest Priority)
Top Tier
1. WMC data in patients with gastric and colonic dysmotility | 1
2. WMC data in nondiseased populations | 2
3. Rates of test failures and need for additional tests | 3
4. WMC diagnostic accuracy and safety in gastroparesis subtypes | 4
5. Thresholds | 5
6. Correlation between WMC values and histopathology | 6
Other Gaps
7. Colonic pressure patterns following meal ingestion. | 7
8. Relation of baseline WMC values with long-term followup values | 8
9. WMC data compared with other tests in nondiseased populations | 9
10. Concurrent tests | 10
11. Masking interpreters of WMC data | 11
12. Use of historical controls in WMC research | 12

M = methodological knowledge gap; WMC = wireless motility capsule

The gap topics and questions were reviewed by the stakeholder panel in two lists to allow them to comment, suggest and rank important issues for both the directly important clinical issues, and the foundational and methodological questions.

The clinical research gaps (Table B) were framed to reflect the clinical gaps in the main evidence report more specifically as relevant to clinical providers. The highest ranked question reflected the uncertainty in the role of the WMC in outcomes for patients with presumed gastroparesis and the role of the WMC as a replacement test versus adjunct test for diagnosis. Consensus guidelines suggest that WMC testing is a replacement for current testing methods, however additional research would lend more weight to that argument. It is currently very difficult in active practice to get access to the WMC for some patients due to lack of insurance coverage, but further research might be more convincing to payers that there is a benefit in this new test and might enable greater access to the WMC. This is clearly a high priority.

The other top ranked question asked whether these same patients with suspected gastroparesis would have comparable results from scintigraphy, anteroduodenal manometry, plain x-ray after marker blind capsule ingestion, endoscopy, or a combination of tests. Similarly, the next ranked questions asked to identify which test should serve as the gold standard or reference standard for comparison, and whether a confirmatory test is required after use of the WMC. Reproducibility of the WMC was also thought to be important and ties into the previous questions which tried to establish the role of WMC testing. Beyond these questions on gastroparesis, the next set of questions focused on slow-transit constipation, including establishing the role of WMC testing in diagnosis compared with other standard tests for ability to diagnose, as well as accuracy and safety in diagnosis.

The next series of questions asked about the incremental value of WMC testing in addition to other testing methods for gastric emptying delay and slow-transit constipation. Interestingly, the top tier included questions about correlating pathology with clinical history and WMC findings. This echoes the questions from the foundational side asking about the same correlation. Also, a focus was the role of WMC testing in colonic dysmotility to predict outcomes, or to predict the effects of medical and/or surgical therapy on outcomes.

The most highly ranked foundational questions (Table C) made clear that basic data ranges for WMC testing have yet to be firmly established in non-diseased populations and those with suspected gastric or colonic dysmotility. With better established norms for diseased and non-diseased patients, there can be better framing of future questions and research endeavors. The next most highly ranked questions were very similar to the initial research questions addressed in our evidence report, which had only low strength of evidence. With additional high quality research, the panel thought that the strengths and weaknesses of WMC testing would be more apparent. Thus, they suggested a priority area for research would be future studies that focus on establishing the role of WMC testing comparatively with scintigraphy, manometry, and radiopaque markers or that focus on obtaining information about test failure and the need for additional tests. It was also considered important to assess diagnostic accuracy of the test when used by non-academic specialists or as a front-line test. Other priority items included establishing the thresholds of diagnostic accuracy and establishing the basic science connection between WMC results and histopathological findings from patients with known disease, if one exists. All of these basic foundational questions were ranked highly by participants in both rounds. These are by definition high-priority areas for future research.

### Research Needs

The gap topics and questions were reviewed by the stakeholder panel in two lists to allow them to comment, suggest and rank important issues for both the directly important clinical issues, and the foundational and methodological questions. We received suggestions for additional research questions, which were solicited at the first round of survey, and then subject to general review at the second round of questions. Our expert panel readily identified these areas as necessary and important during both rounds of feedback and, specifically, they focused on certain questions of greater importance. The global rankings demonstrate a delineation of the most highly valued and frequently chosen topics from the least valued and least frequently selected items. The top half of the priority ranked questions were chosen as the top tier, and are considered the highest priority research needs. Next we developed a list of research questions based on the research needs (i.e., a top tier of prioritized evidence gaps) with sufficient detail for use by researchers and funders (in PICOTS format: population, intervention, comparisons, outcomes, timing, setting), including recommendations on research designs that would best suit each research question (Table D). The clinical questions focus on the basic clinical needs in research on WMC testing. The methodological questions address the relationships of WMC data to other diagnostic test result ranges and to the basic biology of the normal and diseased digestive tract. Other questions address basic research principles needed to study the WMC properly. The answers to the latter questions will provide firm underpinnings for future research.

Table D Summary of research needs (top tier)

Gap | Question | Population | Intervention | Comparator | Outcomes | Timing^a^ | Setting | Potential Study Designs
Clinical Questions
1. Comparative effectiveness of managing with WMC (gastric dysmotility/gastroparesis) | Among patients with [underlined: presumed gastroparesis], how do clinical outcomes differ between patients managed with WMC data alone versus those managed with scintigraphy data alone? | Presumed gastroparesis | WMC alone | 4 hour gastric scintigraphy by standard protocol (ANMS consensus) | Clinical outcomes – diagnostic accuracy, harms, motility assessment, tolerability, treatment decisions, patient centered outcomes – symptom improvement, quality of life resource utilization | Simultaneous | Academic, multi-center practice | Randomized, controlled trial, prospective
2. Comparative diagnostic accuracy and safety (gastric dysmotility/gastroparesis) | Among patients with [underlined: suspected gastroparesis], how does the WMC compare with gastric scintigraphy, antroduodenal manometry, and endoscopy in its accuracy and safety in diagnosing gastroparesis? | Suspected gastroparesis | WMC alone | 4 hour gastric scintigraphy by standard protocol (ANMS consensus), or antroduodenal manometry and/or endoscopy | Clinical outcomes – diagnostic accuracy, harms, motility assessment, tolerability, treatment decisions, patient centered outcomes – symptom improvement, quality of life resource utilization | | Academic, multicenter practice | Randomized, controlled trial, prospective
3. Gold standard (gastric dysmotility/gastroparesis) | What is an appropriate test (gold standard) to compare with WMC in the diagnosis and monitoring of patients with [underlined: gastroparesis]? (e.g., clinical diagnosis, 4-hour gastric scintigraphy, antroduodenal manometry, endoscopy, plain X-ray of the abdomen 5 hours after swallowing a “dumb” radiopaque pill, a combination of tests) | Suspected or known gastroparesis subjects | WMC alone | Clinical history, standardized GI questionnaire, 4 hour gastric emptying, antroduodenal manometry, endoscopy, plain x ray 5 hours after swallowing a patency capsule, or some combination above | Clinical outcomes – diagnostic accuracy, harms, motility assessment, tolerability, treatment decisions, patient centered outcomes – symptom improvement, quality of life resource utilization | | Academic, multicenter practice | Randomized controlled prospective trial, or prospectively enrolled but retrospectively reviewed cases, blinded interpretation of results
4. Comparison of WMC and scintigraphy results (gastroparesis) | In the clinical evaluation of patients with suspected gastroparesis, do abnormal WMC gastric emptying times correlate with 4-hour gastric scintigraphy results well enough to replace scintigraphy, or is a confirmatory scintigraphy required after an abnormal WMC test? | Suspected gastroparesis | WMC alone | 4 hour gastric scintigraphy or WMC plus gastric scintigraphy | Clinical outcomes – diagnostic accuracy, harms, motility assessment, tolerability, treatment decisions, patient centered outcomes – symptom improvement, quality of life resource utilization | | Academic multicenter practice | Randomized controlled prospective trial, not device funded, blinded interpretation of results
5. Gold standard (colonic dysmotility/slow-transit constipation) | What is an appropriate test (gold standard) to compare with WMC in the diagnosis and monitoring of patients with slow-transit constipation? (e.g., clinical diagnosis, colonic scintigraphy, radiopaque markers, a combination of tests) | Suspected Slow transit constipation | WMC alone | Clinical history, GI questionnaire, colonic scintigraphy, radiopaque markers, combinations of tests | Clinical outcomes – diagnostic accuracy, diagnostic gain with additional tests, safety, tolerability | | Academic practice with scintigraphy available – caveat that scintigraphy is very expensive and this study may be prohibitively expensive | Randomized controlled prospective, blinded interpretation of results
6. Reproducibility of WMC results (gastroparesis) | In normal patients and those with gastroparesis, how reproducible are WMC studies performed 2 weeks apart? | Normal and suspected gastroparesis | WMC | Repeat WMC at later time | Reproducibility of test results, change in specificity or sensitivity with two tests as compared with one | | Any, preferably academic | Prospective, Blinded review, all patients receive same intervention.
7. Comparative diagnostic accuracy and safety (colonic dysmotility/slow-transit constipation) | Among patients with suspected slow-transit constipation how does the WMC compare with radiopaque markers and scintigraphy in accuracy in diagnosis and safety? | Suspected Slow transit constipation | WMC | Radiopaque markers, colonic scintigraphy | Accuracy, Safety | | Any | Prospective, blinded interpretation, followed at 1 and 30 days for harms
8. Incremental diagnostic accuracy (gastric dysmotility/gastroparesis) | What is the incremental value of WMC in addition to gastric scintigraphy, antroduodenal manometry or endoscopy to diagnose delayed gastric emptying or dysmotility? | Suspected gastric emptying delay | WMC | Gastric scintigraphy, antroduodenal manometry, endoscopy | Incremental value in diagnosis | | Any | Blinded review of results, controlled trial, could examine cohorts
9. Best test or combination for predicting outcomes after colectomy (colonic dysmotility/slow-transit constipation) | Among patients with confirmed colonic dysmotility who undergo colectomy, is WMC data alone, or scintigraphy plus radiopaque markers, or the combination of all three the best predictor of whole gut dysmotility and clinical outcomes? | Confirmed colonic dysmotility patients who post test(s) have undergone or not undergone colectomy | WMC | Scintigraphy, radiopaque markers, combination of all three | Clinical outcomes – diagnostic accuracy, harms, motility assessment, tolerability, treatment decisions, patient centered outcomes – symptom improvement, quality of life resource utilization | | Any | Retrospective with prospectively collected data.
Methodological Questions
1. WMC data in patients with gastric and colonic dysmotility | Among patients with gastric and colonic dysmotility, what are the ranges of WMC values for temperature, pH, pressure pattern and transit time in the stomach, intestines and colon? | Suspected gastric and suspected colonic dysmotility | WMC | Ranges of normal, no comparators needed | Temperature, pH, pressure patterns, transit time | | Any | Prospective enrolled, blinded review, with confirmatory second reviewer to calculate kappa
2. WMC data in non-diseased populations | In non-diseased populations, what are the distributions of age-, race- and sex-specific values for pressure patterns/amplitude/frequency, temperature, pH, and transit time in the stomach, intestines and colon, as measured by the WMC? | Healthy patients, multiple ages, all sexes | WMC | Ranges of normal, comparators would be in patients of different ages and sexes | Temperature, ph, pressure patterns, transit time | | Any | Prospective enrolled, blinded review
3. Rates of test failures and need for additional tests | How does the WMC compare with scintigraphy, manometry and radiopaque markers in the rates of test failures and need for additional tests? | Suspected gut dysmotility patients | WMC | Scintigraphy, manometry, radiopaque markers | Diagnostic accuracy, Test failure, need for additional tests | | Any | Randomized, prospective, also could collect data prospectively and retrospectively analyze as ultimate outcome becomes available
4. WMC diagnostic accuracy and safety in gastroparesis subtypes | How do the diagnostic accuracy, safety and resource utilization of the WMC differ when used in ambulatory gastroenterology clinics and primary care offices - and when the WMC results are interpreted by primary gastroenterologists, primary care physicians or nurse practitioners? | Ambulatory general gastroenterology patients and primary care physicians offices, suspected motility disorder with symptoms of gastric emptying delay or colonic transit abnormality | WMC | Clinical diagnosis | Diagnostic accuracy, safety, resource utilization | | Ambulatory gastroenterology practice and primary care offices | Prospective trial, observation in practice due to concerns over difficulties with randomizing at multiple local physicians offices.
5. Thresholds | What thresholds should be used to differentiate diagnostic accuracy between the WMC and another test? (e.g., sensitivity, specificity, % agreement, other) | Any populations, healthy vs. diseased | WMC | Other testing modalities, what threshold differentiates effectively | Threshold optimal range for determining diagnostic accuracy | | Any | Statistical analysis based on above data to determine optimal thresholds, would need data from other trials to calculate.
6. Correlation between WMC values and histopathology | Among patients with motility disorders, are WMC values correlated with the histopathological findings from full-thickness or standard biopsy? | Gastric or colonic dysmotility or general gut dysmotility patients | WMC | Histopathology samples or genetic samples from patients with known disease | Clinical outcomes – diagnostic accuracy, harms, motility assessment, tolerability, treatment decisions, patient centered outcomes – symptom improvement, quality of life resource utilization | | Academic center, with experience in genetics and tissue banking also neurogastro staining techniques | Prospectively collected registry information that can be correlated with ongoing genetic and advanced neurogastroenterological pathology diagnostic techniques as they become available

ANMS = American Neurogastroenterology and Motility Society; GI = gastrointestinal; WMC = wireless motility capsule

a Timing field left blank if there were no salient timing issues.

### Ongoing Research

We scanned trial registries (Appendix A) for any ongoing clinical trials which may have already addressed these high-priority areas (Appendix B). We found two clinicaltrials.gov references which had already published the results on populations outside of the scope of our review, spinal cord injury patients and critically ill intensive care patients. One clinicaltrials.gov reference was not assessing the role of wireless motility capsule in diagnosis of constipation or gastroparesis, but instead focused on acid measurement. We also identified a funded research protocol, which likely has yet to complete enrollment, regarding effect of medication for constipation on outcomes with wireless motility capsule. We await the outcome of this trial, but it is only representative of one of many treatment modalities available to these patients. No other ongoing research projects were identified which address the questions we designed.

## Discussion

Our method of determining Future Research Needs has strengths and limitations. One issue was the narrow scope of our original evidence report, which focused on gastroparesis and constipation and the comparative role of WMC testing. Since our initial review did not try to analyze small bowel transit or whole gut transit abnormalities as part of the review process, some aspects of the potential benefit of WMC testing may not have been established by our work. Further, by focusing primarily on WMC testing, we may not have captured all of the needs for research on the evaluation of gastroparesis and constipation. However, after thorough analysis of the data, clear gaps were seen on the methodological side and on the clinical side of research on gastroparesis and slow-transit constipation with regard to WMC testing.

We used an abbreviated Delphi technique to determine the priorities of the stakeholders. In the first round, the stakeholders varied widely in the priorities they assigned to the various gaps. In the second round, the stakeholders still showed moderate variation in their priorities. This finding is not surprising, given that we intentionally recruited stakeholders having very different perspectives.

We included a limited number of stakeholders, and thus may not have a totally representative view of all relevant stakeholders. It would have taken much longer to collect information from more stakeholders, however, a larger group would have required review and approval by the Office of Management and Budget. We deliberately recruited individuals with different perspectives to gain insight from key stakeholder groups. The participating stakeholders included clinical experts, methodologic experts, and a patient/consumer advocate. Collectively, their thoughtful comments were indispensable in creating this FRN report.

The highest priority clinical and methodological gaps and questions are shown in Table E. To develop clinically accurate recommendations for providers and payers, we urgently need additional studies of these questions to help guide the development of formal evidence-based guidelines to replace the current consensus guidelines, which are based on limited evidence.

Table E Top-tier research priorities listed in order

Clinical Questions
Among patients with presumed gastroparesis, how would clinical outcomes differ between patients managed with WMC data alone versus those managed with scintigraphy data alone?
Among patients with suspected gastroparesis, how does the WMC compare with gastric scintigraphy, antroduodenal manometry, and endoscopy in its accuracy and safety in diagnosing gastroparesis?
What is an appropriate comparison test (gold standard) to which the WMC should be compared in the diagnosis and monitoring of patients with gastroparesis (e.g., clinical diagnosis, 4-hour gastric scintigraphy, antroduodenal manometry, endoscopy, plain X-ray of the abdomen 5 hours after swallowing a “dumb” radiopaque pill, a combination of tests)?
In the clinical evaluation of patients with suspected gastroparesis, do abnormal WMC gastric emptying times correlate with 4-hour gastric scintigraphy results well enough to replace scintigraphy, or is a confirmatory scintigraphy required after an abnormal WMC test?
What is an appropriate comparison test (gold standard) to which the WMC should be compared in the diagnosis and monitoring of patients with slow-transit constipation (e.g., clinical diagnosis, colonic scintigraphy, radiopaque markers, a combination of tests)?
In normal patients and those with gastroparesis, how reproducible are WMC studies performed 2 weeks apart?
Among patients with suspected slow-transit constipation how does the WMC compare with radiopaque markers and scintigraphy in its accuracy and safety of diagnosis?
What is the incremental value of using the WMC in addition to gastric scintigraphy, antroduodenal manometry or endoscopy to diagnose delayed gastric emptying or dysmotility?
Among patients with confirmed colonic dysmotility who undergo colectomy, is WMC data alone, or scintigraphy plus radiopaque markers, or the combination of all three the best predictor of whole gut dysmotility and clinical outcomes?
Methodological Questions
Among patients with gastric and colonic dysmotility, what are the ranges of WMC values for temperature, pH, pressure pattern and transit time in the stomach, intestines and colon?
In non-diseased populations, what are the distributions of age-, race- and sex-specific values for pressure patterns/amplitude/frequency, temperature, pH, and transit time in the stomach, intestines and colon, as measured by the WMC?
How does the WMC compare with scintigraphy, manometry, and radiopaque markers in the rates of test failures and need for additional tests?
How do the diagnostic accuracy, safety, and resource utilization of the WMC differ when used in ambulatory gastroenterology clinics and primary care offices - and when the WMC results are interpreted by primary gastroenterologists, primary care physicians, or nurse practitioners?
What thresholds should be used to differentiate diagnostic accuracy between the WMC and another test (e.g., sensitivity, specificity, % agreement, other)?
Among patients with motility disorders, are WMC values correlated with the histopathological findings from full-thickness or standard biopsy?

WMC = wireless motility capsule

## Conclusions

Evidence exists to support use of WMC testing for the detection, diagnosis, treatment and management of gastric and colonic dysmotility, but much of the evidence is either low strength or insufficient for making evidence-based recommendations. We focused on creating a compelling set of research questions, which was reviewed by a group of stakeholders and revised into a tiered list of priorities for future research. Future research to answer these questions will help to improve care by establishing a stronger evidence base for the use of WMC testing, potentially leading to improved diagnosis, detection, treatment and management of motility disorders, which have had few tools for accurate, reliable, portable, non-radiating, standardized diagnosis in the past. Although colonic and gastric dysmotility are not as common as high blood pressure or diabetes, the burden of disease for gastroparesis and severe colonic dysmotility is great. Accurate and rapid diagnosis on a consistent basis would be a cornerstone for conducting future research on the clinical outcomes of homogeneous groups of dysmotility patients.

## References

1 Hasler WL. Gastroparesis: pathogenesis, diagnosis and management. Nat Rev Gastroenterol Hepatol. 2011;8(8):438-53. [pmid: 21769117].
2 Camilleri M, Bharucha AE, Farrugia G. Epidemiology, mechanisms, and management of diabetic gastroparesis. Clin Gastroenterol Hepatol. 2011;9(1):5-12. quiz e7. [pmid: 20951838].
3 Wang YR, Fisher RS, Parkman HP. Gastroparesis-related hospitalizations in the United States: trends, characteristics, and outcomes, 1995-2004. Am J Gastroenterol. 2008;103(2):313-22. [pmid: 18047541].
4 Rao SS, Kuo B, McCallum RW, et al. Investigation of colonic and whole-gut transit with wireless motility capsule and radiopaque markers in constipation. Clin Gastroenterol Hepatol. 2009;7(5):537-44. [pmid: 19418602].
5 Stewart WF, Liberman JN, Sandler RS, et al. Epidemiology of constipation (EPOC) study in the United States: relation of clinical subtypes to sociodemographic features. Am J Gastroenterol. Dec. 1999;94(12):3530-40. [pmid: 10606315].
6 Suares NC, Ford AC. Prevalence of, and risk factors for, chronic idiopathic constipation in the community: systematic review and meta-analysis. Am J Gastroenterol. Sep. 2011;106(9):1582-91. quiz 1, 92. [pmid: 21606976].
7 Ribas Y, Saldana E, Marti-Rague J, et al. Prevalence and pathophysiology of functional constipation among women in Catalonia, Spain. Dis Colon Rectum. Dec. 2011;54(12):1560-9. [pmid: 22067186].
8 Rao SS, Ozturk R, Laine L. Clinical utility of diagnostic tests for constipation in adults: a systematic review. Am J Gastroenterol. 2005;100(7):1605-15. [pmid: 15984989].
9 Brandt LJ, Prather CM, Quigley EM, et al. Systematic review on the management of chronic constipation in North America. Am J Gastroenterol. Suppl 1. 2005;100:S5-S21. [pmid: 16008641].