# Acknowledgments

## Contributors

- Thomas Abell, M.D.
  University of Mississippi Medical Center
  Jackson, MS
- Mary-Angela DeGrazia-DiTucci
  Patient and Advocate
  Association of Gastrointestinal Motility Disorders, Inc.
  Bedford, MA
- Gianrico Farrugia, M.D.
  Mayo Clinic
  Rochester, MN
- Lauren B. Gerson, M.D., M.Sc.
  Stanford University School of Medicine
  Palo Alto, CA
- Richard McCallum, M.D.
  Texas Tech University
  El Paso, TX
- Henry Parkman, M.D.
  Temple University School of Medicine
  Philadelphia, PA
- Pankaj Jay Pasricha, M.D.
  Stanford Medical Center
  Palo Alto, CA
- Satish Rao, M.D.
  University of Iowa Health Care
  Iowa City, IA
- Holger Schunemann, M.D., Ph.D.
  McMaster University
  Hamilton, Ontario, Canada