# Discussion

The diagnosis and management of motility disorders is complex. In part it is difficult because our current testing modalities are suboptimal and hard to standardize. In part it is complicated by patient factors, like medications, which interfere with testing, or medical conditions like diabetes which tend to make patients worse over time. Also, patients often have more than one disorder, and a substantial percentage will have both gastric and colonic dysmotility at the same time. In addition, although patients with gastroparesis and constipation are often lumped in one category clinically, these patients likely represent different clinical phenotypes with different underlying pathophysiology and presumably different responses to treatment. It is unclear how objective measures of dysmotility (such as impaired gastric emptying) are related to symptoms as many studies have not shown a clear correlation between treatment response and objective motility improvement.

There is a burgeoning population of patients with gastroparesis, estimated at 1.5 to 3 million Americans, by some models. Based on current trends in obesity and diabetes, this problem has the potential to compound over the next 10 to 20 years. Measures taken now to invest in establishing good diagnostic tests and deciding about whether or not WMC is a useful modality will have a large impact on costs and may have potential impact on management of these diseases.

Our method of determining FRN has strengths and limitations. One problem was the narrow scope of our original evidence report focusing on gastroparesis and constipation and the comparative role of WMC testing. Since our initial review did not include small bowel transit or whole gut transit abnormalities in the review, some aspects of the potential benefit of WMC testing may not have been established by our work. By focusing primarily on WMC testing, we may not have captured all of the needs for research on the evaluation of gastroparesis and constipation. However, after thorough analysis of the data, clear gaps were seen in the methodological side and clinical side of research on gastroparesis and slow transit constipation with relation to WMC testing. We did not include gaps in basic science of neurogastroenterology, but we know there are many areas of ongoing research into this area which may also need to be assessed. This was beyond the scope of the original review.

Due to time constraints related to the desire to prepare a report on FRN as soon as possible after completion of the evidence report, we used an abbreviated Delphi technique to determine the priorities of the stakeholders. In the first round of the group judgment process, the stakeholders varied widely in the priorities they assigned to the gaps. In the second round of the process, the stakeholders still showed moderate variation in their priorities, indicating that there was not total consensus on the priorities. This finding is not surprising, however, given that we intentionally included stakeholders having very different perspectives. Nonetheless, the process revealed a number of gaps that different stakeholders considered very important to address.

We had a limited number of stakeholders, and thus may not have a totally representative view of all relevant stakeholders. It would have taken longer to collect information from more stakeholders because a larger group would require review and approval by the Office of Management and Budget. Our stakeholders represented the important perspectives, by including clinical experts, methodologic experts, a patient/consumer advocate. Together, they identified high priorities for future research. Their thoughtful comments were very useful in creating the FRN report.

The summative results of the high-priority research items showed a consistent pattern of identifying many of the same issues and questions that were identified in the original systematic review. The original questions posed were often selected again here for further research inquiry.