# Conclusion

There is evidence for WMC in many areas of clinical use for the detection, diagnosis, treatment and management of gastric and colonic dysmotility, however much of the evidence was either low strength or insufficient for making evidence-based recommendations. We focused on creating a viable set of research questions, which was reviewed by an expert panel and revised into a tiered list of priorities for future research. These FRN will help to immediately impact care by establishing firmly the evidence-base for use of WMC and potentially lead to improved diagnosis, detection, treatment and management of motility disorders which have had few tools for accurate, reliable, portable, non-radiating standardized diagnosis in the past. Although colonic and gastric dysmotility are not as common as high blood pressure or diabetes, the burden of disease for gastroparesis and severe colonic dysmotility is great, and accurate and rapid diagnosis on a consistent basis would be the cornerstone of developing research projects to reliably compare patients with similar disease characteristics to each other. We urgently need these additional studies to help guide the development of formal evidence-based guidelines as compared with the current consensus guidelines based on limited evidence to develop clinically meaningful recommendations for providers and payers. The top tier of research priorities are listed in Table 7.

Table 7 Top-tier research priorities listed in order

Clinical Questions
Among patients with [underlined: presumed gastroparesis], how would clinical outcomes differ between patients managed with WMC data alone versus those managed with scintigraphy data alone?
Among patients with [underlined: suspected gastroparesis], how does the WMC compare with gastric scintigraphy, antroduodenal manometry, and endoscopy in its accuracy and safety in diagnosing gastroparesis?
What is an appropriate comparison test (gold standard) to which the WMC should be compared in the diagnosis and monitoring of patients with [underlined: gastroparesis] (e.g., clinical diagnosis, 4-hour gastric scintigraphy, antroduodenal manometry, endoscopy, plain X-ray of the abdomen 5 hours after swallowing a “dumb” radiopaque pill, a combination of tests)?
In the clinical evaluation of patients with suspected [underlined: gastroparesis], do abnormal WMC gastric emptying times correlate with 4-hour gastric scintigraphy results well enough to replace scintigraphy, or is a confirmatory scintigraphy required after an abnormal WMC test?
What is an appropriate comparison test (gold standard) to which the WMC should be compared in the diagnosis and monitoring of patients with [underlined: slow-transit constipation] (e.g., clinical diagnosis, colonic scintigraphy, radiopaque markers, a combination of tests)?
In normal patients and those with [underlined: gastroparesis], how reproducible are WMC studies performed 2 weeks apart?
Among patients with suspected [underlined: slow-transit constipation] how does the WMC compare with radiopaque markers and scintigraphy in its accuracy and safety of diagnosis?
What is the incremental value of using the WMC in addition to gastric scintigraphy, antroduodenal manometry or endoscopy to diagnose delayed gastric emptying or dysmotility?
Among patients with confirmed [underlined: colonic dysmotility] who undergo colectomy, is WMC data alone, or scintigraphy plus radiopaque markers, or the combination of all three the best predictor of whole gut dysmotility and clinical outcomes?
Methodological Questions
Among patients with gastric and colonic dysmotility, what are the ranges of WMC values for temperature, pH, pressure pattern and transit time in the stomach, intestines and colon?
In non-diseased populations, what are the distributions of age-, race- and sex-specific values for pressure patterns/amplitude/frequency, temperature, pH, and transit time in the stomach, intestines and colon, as measured by the WMC?
How does the WMC compare with scintigraphy, manometry and radiopaque markers in the rates of test failures and need for additional tests?
How do the diagnostic accuracy, safety and resource utilization of the WMC differ when used in ambulatory gastroenterology clinics and primary care offices - and when the WMC results are interpreted by primary gastroenterologists, primary care physicians or nurse practitioners?
What thresholds should be used to differentiate diagnostic accuracy between the WMC and another test (e.g., sensitivity, specificity, % agreement, other)?
Among patients with motility disorders, are WMC values correlated with the histopathological findings from full-thickness or standard biopsy?

WMC = wireless motility capsule