# Individual Stakeholder Priority Scores for Future Research Questions

Topic | Stakeholder 1 | Stakeholder 2 | Stakeholder 3 | Stakeholder 4 | Stakeholder 5 | Stakeholder 6 | Stakeholder 7 | Stakeholder 8 | Stakeholder 9 | Sum (highest sum = highest priority) | Priority Rank (1 = highest priority)
List 1: Clinical Research The individual stakeholder ratings have been inverted so that the highest value (6) is the highest priority.
Top Tier
1. Comparative effectiveness of managing with WMC (gastric dysmotility/gastroparesis) | 6 | 4 | | 6 | | | | 4 | 6 | 26 | 1
2. Comparative diagnostic accuracy and safety (gastric dysmotility/gastroparesis) | 4 | | 6 | 4 | 4 | | 5 | | | 23 | 2
3. Gold standard (gastric dysmotility/gastroparesis) | | | | 1 | 6 | 6 | 6 | | | 19 | 3
4. Comparison of WMC and scintigraphy results (gastroparesis) | | 6 | 4 | | | | | 3 | 5 | 18 | 4
5. Gold standard (colonic dysmotility/slow-transit constipation) | | | | | 5 | 5 | 4 | | | 14 | 5
6. Reproducibility of WMC results (gastroparesis) | | 5 | | 2 | | 4 | | | 3 | 14 | 5
7. Comparative diagnostic accuracy and safety (colonic dysmotility/slow-transit constipation) | | | 5 | 5 | 1 | | | | | 11 | 6
8. Incremental diagnostic accuracy (gastric dysmotility/gastroparesis) | | | | | 3 | | 2 | 5 | | 10 | 7
9. Incremental diagnostic accuracy (colonic dysmotility/slow-transit constipation) | | | | | 2 | | 1 | 6 | | 9 | 8
Other Gaps
10. Distinction of subtypes of gastroparesis (gastric dysmotility/gastroparesis) | | 1 | | | | 2 | | | 4 | 7 | 9
11. Best test or combination for predicting outcomes after colectomy (colonic dysmotility/slow-transit constipation) | 5 | | | | | | | | 2 | 7 | 9
12. Comparative accuracy in predicting response to treatment (colonic dysmotility/slow-transit constipation) | 3 | 3 | | | | 1 | | | | 7 | 9
13. Utility of colonic pressure (colonic dysmotility) | 1 | | 1 | | | | | 2 | 1 | 5 | 10
14. Differentiating IBS-C from idiopathic constipation (colonic dysmotility/slow-transit constipation) | | 2 | | | | 3 | | | | 5 | 10
15. Comparisons of WMC pressure profiles (gastroparesis) | | | 2 | 3 | | | | | | 5 | 10
16. Best test or combination for predicting outcomes without colectomy (colonic dysmotility/slow-transit constipation) | | | 3 | | | | | 1 | | 4 | 11
17. Comparative accuracy in predicting response to treatment (gastric dysmotility/gastroparesis) | 2 | | | | | | | | | 2 | 12
18. Comparative value in monitoring response to treatment (gastric dysmotility/gastroparesis) | | | | | | | | | | 0 | 13
19. Comparative value in monitoring response to treatment (colonic dysmotility/slow-transit constipation) | | | | | | | | | | 0 | 13
20. Colonic pressure patterns after waking (colonic dysmotility) | | | | | | | | | | 0 | 13
21. Evaluation of high-amplitude contractions (colonic dysmotility) | | | | | | | | | | 0 | 13
List 2: Questions Involving Methodological Research
Top Tier
1. WMC data in patients with gastric and colonic dysmotility* | 3 | 6 | 5 | 7 | 6 | 7 | 6 | 6 | 1 | 47 | 1
2. WMC data in non-diseased populations* | 2 | 7 | 4 | | 7 | 4 | 7 | 7 | 2 | 40 | 2
3. Rates of test failures and need for additional tests* | 6 | | 6 | 5 | 5 | | 4 | 3 | 5 | 34 | 3
4. WMC diagnostic accuracy and safety in gastroparesis subtypes* | 7 | 4 | | 3 | 4 | 5 | 1 | 5 | | 29 | 4
5. Thresholds* | | 5 | 7 | | 3 | 6 | 5 | 1 | | 27 | 5
6. Correlation between WMC values and histopathology* | | | | 6 | | 1 | | 4 | 7 | 18 | 6
Other Gaps
7. Colonic pressure patterns following meal ingestion. | 5 | 2 | | 4 | 1 | | | | 3 | 15 | 7
8. Relation of baseline WMC values with long-term followup values | 1 | 3 | | | | | 3 | | 6 | 13 | 8
9. WMC data compared with other tests in non-diseased populations | 4 | | 3 | | 2 | 3 | | | | 12 | 9
10. Concurrent tests | | | 1 | 2 | | 2 | | | 4 | 9 | 10
11. Masking interpreters of WMC data | | 1 | | | | | 2 | 2 | | 5 | 11
12. Use of historical controls in WMC research | | | 2 | | | | | | | 2 | 12

C = clinical knowledge gap; M = methodological knowledge gap; WMC = wireless motility capsule.