# List of Ongoing Studies

Title/ Identifier(s) | Study Dates | Description | Sponsor or Principal Investigator Collaborator(s) | Source
Title: Lubiprostone Effect on Gastrointestinal (GI) Tract Transit Times Measured by Smartpill in Patients With Chronic Constipation Identifier(s): NCT01469819 | Start date: November 2011 Estimated study completion date: December 2012 Estimated primary completion date: December 2012 (Final data collection date for primary outcome measure) | Purpose: To measure the time difference in the duration of transit of the FDA approved SmartPill capsule in all segments of gastrointestinal (GI) tract before and after exposure to lubiprostone. Study design: Endpoint Classification: Efficacy Study Intervention Model: Single Group Assignment Masking: Open Label Primary Purpose: Treatment Condition(s): Chronic Idiopathic Constipation Intervention(s): Drug: Lubiprostone Estimated enrollment: 15 | Texas Tech University Health Sciences Center Takeda Pharmaceuticals North America, Inc. | ClinicalTrials.gov Accessed at: clinicaltrials.gov/ct2/show/NCT01469819
Title: SmartPill Monitoring for Assessment of GI Function in SCI Identifier(s): NCT00856648 | Start date: April 2009 Estimated study completion date: December 2011 Estimated primary completion date: April 2011 (Final data collection date for primary outcome measure) | Purpose: To evaluate the relationship between the level of SCI and the impairment of Colonic transit time (CTT) and Total transit time (TTT) by using the SmartPill device. Study design: Observational Model: Case Control Time Perspective: Prospective Condition(s): SCI Intervention(s): Device: SmartPill ingestion and monitoring Estimated enrollment: 40 | Department of Veterans Affairs | ClinicalTrials.gov Accessed at: clinicaltrials.gov/ct2/show/NCT00856648
Title: A New Method for Determining Gastric Acid Output Using a Wireless Capsule Identifier(s): NCT00702533 | Start date: June 2008 Estimated study completion date: Ongoing (Currently recruiting participants) Estimated primary completion date: Ongoing (currently recruiting participants) | Purpose: To evaluate the usefulness and accuracy of the SmartPill for gastric analysis, compared with current procedures. Study design: Observational, Time Perspective: Prospective Condition(s): Gastrointestinal Diseases Intervention(s): Wireless Capsule SmartPill Estimated enrollment: 80 | National Institute of Diabetes and Digestive and Kidney Diseases | ClinicalTrials.gov Accessed at: clinicaltrials.gov/ct2/show/NCT00702533
Title: Evaluation of Gastrointestinal Motility With SmartPill Identifier(s): NCT01159002 | Start date: November 2007 Estimated study completion date: January 2009 Estimated primary completion date: May 2008 (Final data collection date for primary outcome measure) | Purpose: To evaluate the clinical usefulness of a capsule (SmartPill∼) measuring pH, pressure and temperature from within the entire GI tract to determine gastric emptying time, combined small and large bowel transit time and total transit time. Study design: Observational Model: Cohort Time Perspective: Prospective Condition(s): Gastrointestinal Motility Intervention(s): Device: SmartPill Estimated enrollment: 8 | University of Louisville | ClinicalTrials.gov Accessed at: clinicaltrials.gov/ct2/show/NCT01159002