# Search Strategy for Ongoing Studies

Resource URL | Search Parameters | Search Terms/Strategy
ClinicalTrials.gov clinicaltrials.gov/ | Advanced search, Conditions field used | Wireless motility capsule OR Smartpill
EU Clinical Trials Register www.clinicaltrialsregister.eu/ | Not applicable | Wireless motility capsule OR Smartpill
NIH Reporter projectreporter.nih.gov/reporter.cfm | Projects field searched | Wireless motility capsule OR Smartpill
Canadian Institutes of Health Research www.cihr-irsc.gc.ca/ | Funding Decisions Data field searched | Wireless motility capsule OR Smartpill
World Health Organization International Clinical Trials Registry Platform Search Portal apps.who.int/trialsearch/ | Searched Condition field, Recruitment status = ALL | Wireless motility capsule OR Smartpill