# Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality
ANMS: American Neurogastroenterology and Motility Society
COI: Conflict of Interest
EHC: Effective Health Care
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
FRN: Future Research Needs
KQ: Key Question
PICOTS: Population, Intervention, Comparison, Outcome, Timing, Setting
ROM: Radiopaque Markers
SOE: Strength of evidence
WMC: Wireless motility capsule