# Results

## Research Needs

In phase 1 of the process, the stakeholders identified gaps in evidence concerning populations, medication comparisons, and outcomes that varied for the induction of remission and the maintenance of remission of Crohn's disease. Results from the stakeholder prioritization are presented first as future research needs for the induction of remission and then for the maintenance of remission.

### Induction of Remission

During phase 1 of this review, for the induction of remission in patients diagnosed with Crohn's disease, we identified nine potential populations for whom future research may be a priority (Table 1). We found 13 medication comparisons that are potential gaps in the literature (Table 2) pertaining to induction of remission for Crohn's disease, and 12 potential outcomes of interest (Table 3) for future research. All stakeholders (100%) prioritized children as an important while half prioritized patients with severe disease and non-responders to biologics as important populations for future research (Table 1). Among medication comparisons for induction of remission, only one medication comparison achieved consensus among the stakeholders with 60 percent agreement in phase 2. One stakeholder independently identified three medication comparisons for future research that were not included as part of this assessment.

Table 1 Stakeholder identification and prioritization of populations of greatest importance for future research for the induction of remission in patients diagnosed with Crohn's disease

Phase 1: Identification of Evidence Gaps | Phase 2: Number of Stakeholders Indicating Item Was One of Top 3 Priorities | Phase 3: Stakeholder Prioritization Refinement | Phase 4: Inclusion in Final Research Questions
Children | 6 | * | ‡
Severe disease | 3 | * | ‡
Nonresponders to biologics | 3 | * | ‡
Patients with complications (e.g. fistulizing disease) | 2 | *
Women | 1 | *
Non-Whites | 1 | *
Mild disease | 1 | *
Elderly | 0 | *
Other | 1 | *

* Consensus achieved in previous round, consensus-building round (phase 3) not required.

‡ Identified as a high priority research need

Table 2 Stakeholder identification and prioritization of medication comparisons of greatest importance for future research for the induction of remission in patients diagnosed with Crohn's disease

Phase 1: Identification of Evidence Gaps | Phase 2: Number of Stakeholders Rating Item as One of Top 3 Priorities | Phase 3: Number of Stakeholders Rating Item as One of Top 3 Priorities | Phase 4: Inclusion in Final Research Questions
One TNF-alpha inhibitor versus another TNF-alpha inhibitor | 4 | 6 | ‡
TNF-alpha inhibitor + methotrexate versus steroid + methotrexate | 2 | 0
TNF-alpha inhibitor versus TNF-alpha inhibitor + methotrexate | 2 | 1
TNF-alpha inhibitor versus steroid + (6-mercaptopurine or azathioprine) | 2 | 1
TNF-alpha inhibitor versus natalizumab | 2 | 3 | ‡
TNF-alpha inhibitor + azathioprine versus TNF-alpha inhibitor + methotrexate^†^ | 1 | 0
TNF-alpha inhibitor versus steroid | 1 | 2
TNF-alpha inhibitor + (6-mercaptopurine or azathioprine) versus steroid + (6-mercaptopurine or azathioprine) | 1 | 1
Steroid + (6-mercaptopurine or azathioprine) versus steroid + methotrexate | 1 | 1
TNF-alpha inhibitor versus (6-mercaptopurine or azathioprine) | 0 | 0
TNF-alpha inhibitor versus methotrexate | 0 | 2
TNF-alpha inhibitor versus TNF-alpha inhibitor + (6-mercaptopurine or azathioprine) | 0 | 0
TNF-alpha inhibitor versus steroid + methotrexate | 0 | 0
Other: TNF-alpha inhibitor + azathioprine versus (natalizumab or vedolizumab)^†^ | 1 | 0
Other: TNF-alpha inhibitor + azathioprine versus ustakinumab^†^ | 1 | 0
Other: TNF-alpha inhibitor versus new treatment (e.g. Stelara)^†^ | 0 | 1

TNF: Tumor necrosis factor.

† Stakeholder provided comparison.

‡ Identified as a high priority research need.

Table 3 Stakeholder identification and prioritization of outcomes of greatest importance for future research for the induction of remission in patients diagnosed with Crohn's disease

Phase 1: Identification of Evidence Gaps | Phase 2: Number of Stakeholders Rating Item as One of Top 3 Priorities | Phase 3: Stakeholder Prioritization Refinement | Phase 4: Inclusion in Final Research Questions
Mucosal healing | 6 | * | ‡
Patient reported outcomes | 5 | * | ‡
Crohn's Disease Activity Index | 3 | * | ‡
Steroid reduction | 3 | * | ‡
Surgery | 1 | *
Hospitalization | 0 | *
Mortality | 0 | *
Progressive multifocal leukoencephalopathy | 0 | *
Lymphoma and cancer | 0 | *
Tuberculosis and other infections | 0 | *
Infusion reactions | 0 | *
Bone fractures | 0 | *
Other | 0 | *

* Consensus achieved in previous round, consensus-building round (phase 3) not required.

‡ Identified as a high priority research need.

In phase 3, all stakeholders (100%) prioritized one medication comparison (one TNF-alpha inhibitor versus another TNF-alpha inhibitor) as important for future research and half (50%) identified another medication comparison (a TNF-alpha inhibitor versus natalizumab) as important for future research for the induction of remission in Crohn's disease. Consensus was not achieved on a third medication comparison.

### Maintenance of Remission

During phase 1, for the maintenance of remission in patients diagnosed with Crohn's disease, we identified nine potential populations for whom future research may be a priority (Table 4). We found 11 medication comparisons for which potential gaps in the literature exist (Table 5) pertaining to induction of remission for Crohn's disease and 13 potential outcomes of interest (Table 6) for future research.

Table 4 Stakeholder identification and prioritization of populations of greatest importance for future research for the maintenance of remission in patients diagnosed with Crohn's disease

Phase 1: Identification of Evidence Gaps | Phase 2: Number of Stakeholders Rating Item as One of Top 3 Priorities | Phase 3: Stakeholder Prioritization Refinement | Phase 4: Inclusion in Final Research Questions
Children | 6 | * | ‡
Nonresponders to biologics | 3 | * | ‡
Patients with complications (e.g. fistulizing disease) | 3 | * | ‡
Women | 1 | *
Severe disease | 1 | *
Mild disease | 1 | *
Non-Whites | 0 | *
Elderly | 0 | *
Other | 3 | *

* Consensus achieved in previous round, consensus-building round (phase 3) not required.

‡ Identified as a high priority research need

Table 5 Stakeholder identification and prioritization of medication comparisons of greatest importance for future research for the maintenance of remission in patients diagnosed with Crohn's disease

Phase 1: Identification of Evidence Gaps | Phase 2: Number of Stakeholders Rating Item as One of Top 3 Priorities | Phase 3: Number of Stakeholders Rating Item as One of Top 3 Priorities | Phase 4: Inclusion in Final Research Questions
TNF-alpha inhibitor + (6-mercaptopurine or azathioprine) versus TNF-alpha inhibitor | 4 | 4 | ‡
TNF-alpha inhibitor + (6-mercaptopurine or azathioprine) versus (6-mercaptopurine or azathioprine) | 3 | 2
TNF-alpha inhibitor versus (6-mercaptopurine or azathioprine) | 2 | 2
TNF-alpha inhibitor versus methotrexate | 2 | 2
TNF-alpha inhibitor versus natalizumab | 2 | 0
(6-mercaptopurine or azathioprine) versus methotrexate | 2 | 1
One TNF-alpha inhibitor versus another TNF-alpha inhibitor | 1 | 3 | ‡
TNF-alpha inhibitor + methotrexate versus TNF-alpha inhibitor | 1 | 2
TNF-alpha inhibitor + methotrexate versus methotrexate | 1 | 1
TNF-alpha inhibitor versus placebo | 0 | 0
(6-mercaptopurine or azathioprine) versus placebo | 0 | 0
Other: TNF-alpha inhibitor versus new treatment (that is safer)^†^ | 0 | 1

TNF = tumor necrosis factor.

† Stakeholder provided comparison.

‡ Identified as a high priority research need.

Table 6 Stakeholder identification and prioritization of outcomes of greatest importance for future research for the maintenance of remission in patients diagnosed with Crohn's disease

Phase 1: Identification of Evidence Gaps | Phase 2: Number of Stakeholders Rating Item as One of Top 3 Priorities | Phase 3: Stakeholder Prioritization Refinement | Phase 4: Inclusion in Final Research Questions
Steroid reduction | 4 | * | ‡
Patient reported outcomes | 4 | * | ‡
Crohn's Disease Activity Index | 3 | * | ‡
Mucosal healing | 3 | * | ‡
Surgery | 2 | *
Lymphoma and cancer | 2 | *
Hospitalization | 0 | *
Mortality | 0 | *
Progressive multifocal leukoencephalopathy | 0 | *
Lymphoma and cancer | 0 | *
Tuberculosis and other infections | 0 | *
Infusion reactions | 0 | *
Bone fractures | 0 | *
Other | 0 | *

* Consensus achieved in previous rounds, consensus-building round (phase 3) not required.

‡ Identified as a high priority research need.

All stakeholders again prioritized children as an important population for future research for the maintenance of remission of Crohn's disease. Fifty percent of stakeholders agreed that non-responders to biologics, and patients with complications are important populations to study in future research.

Among medication comparisons for maintenance of remission, two medication comparisons, with variation only in the single-medication control arm, achieved consensus in phase 2 (Table 5). Compiled stakeholder responses regarding medication comparisons from phase 2 were sent to the stakeholders with a request to evaluate and again prioritize the medication comparisons.

In phase 3, four stakeholders (60%) prioritized one medication comparison (TNF-alpha inhibitor and thiopurine versus TNF-alpha inhibitor) as important for future research while half (50%) identified a previously low-ranked medication comparison (one TNF-alpha inhibitor versus another TNF-alpha inhibitor) as important for future research for the induction of remission in Crohn's disease. The medication comparison originally agreed upon by 50 percent of stakeholders (TNF-alpha inhibitor and thiopurine versus thiopurine) failed to achieve consensus in phase 3, ergo this was not included in the final list of research questions.

### Research Questions

Based on stakeholder feedback from phase 2 and phase 3 regarding populations, intervention comparisons, and outcomes, the following research questions were developed for future research and, in order, were prioritized by our stakeholders:

1. For maintenance of remission in adults and children diagnosed with Crohn's disease, what is the comparative effectiveness of a TNF-alpha inhibitor and thiopurine versus a TNF-alpha inhibitor for the outcomes of steroid reduction, patient reported outcomes, CDAI, pediatric CDAI and mucosal healing?
2. For induction of remission in adults and children diagnosed with Crohn's disease, what is the comparative effectiveness of one TNF-alpha inhibitor versus another TNF-alpha inhibitor for the outcomes of mucosal healing, patient reported outcomes, steroid reduction, CDAI and pediatric CDAI?
3. For induction of remission in adults and children diagnosed with Crohn's disease, what is the comparative effectiveness of a TNF-alpha inhibitor versus natalizumab for the outcomes of mucosal healing, patient reported outcomes, steroid reduction, CDAI and pediatric CDAI?
4. For maintenance of remission in adults and children diagnosed with Crohn's disease, what is the comparative effectiveness of one TNF-alpha inhibitor versus another TNF-alpha inhibitor for the outcomes of steroid reduction, patient reported outcomes, CDAI, pediatric CDAI and mucosal healing?

For each of these research questions, the strongest and most appropriate study design is a randomized controlled trial with sufficient duration of follow-up to obtain reasonably precise estimates of the comparative effects on the outcomes of interest. Although studies of the induction of remission in Crohn's disease tend to have a shorter timeframe than studies of the maintenance of remission, even studies of remission need follow-up long enough to provide reliable estimates of the effects on the outcomes that matter most to patients, and clearly long-term remission is important to patients. Thus, long-term follow-up for at least 1 year and preferably for up to 5 years would be extremely valuable, especially for children who are at risk of having adverse effects on growth and development. Future randomized controlled trials that examine these questions about the treatment of Crohn's disease should give careful attention to the problems we found in our systematic review of previously published studies, including: (1) under-representation of non-white, pediatric, and newly diagnosed patients; (2) insufficient sample size to determine whether there are clinically important differences in adverse effects of medications; and (3) inconsistent attention to outcomes beyond measures of disease activity. Due to the difficulty and expense of performing large randomized controlled trials on the comparative effectiveness of medications that have already been approved for use by the Food and Drug Administration, observational studies will have a role to play in future research. However, observational studies of comparative effectiveness will need to incorporate sophisticated risk adjustment methods to account for the many different ways in which patients vary when they initiate treatment for Crohn's disease. In this regard, it would be helpful to distinguish between patients with moderate-to-severe disease and those with mild disease. Long-term follow-up also will be extremely important to capture adverse events that may not be manifest for years after the initiation of treatment.

### Identification of Ongoing Research

We searched clinical research repositories and research-related sites including ClinicalTrials.gov, NIH Reporter, the Canadian Institutes of Health Research, the World Health Organization Clinical Trials Registry, and the European Union Clinical Trials Register to identify ongoing/recently completed studies related to the pharmacological management of Crohn's disease. Appendix Table A-2 includes a summary of findings from these searches. Six potentially relevant studies were identified.