# References

1 Loftus EV Jr, Schoenfeld P, Sandborn WJ. The epidemiology and natural history of crohn's disease in population-based patient cohorts from north america: A systematic review. Aliment Pharmacol Ther. 2002;16(1):51-60. [pmid: 11856078].
2 Bousvaros A, Sylvester F, Kugathasan S, et al. Challenges in pediatric inflammatory bowel disease. Inflamm Bowel Dis. 2006;12(9):885-913. [pmid: 16954808].
3 Lichtenstein GR, Hanauer SB, Sandborn WJ. Practice Parameters Committee of American College of Gastroenterology. Management of crohn's disease in adults. Am J Gastroenterol. 2009;104(2):465. 83. quiz 464, 484. [pmid: 19174807].
4 Korelitz BI. A history of immunosuppressive drugs in the treatment of inflammatory bowel disease: Origins at the mount sinai hospital. Mt Sinai J Med. May. 2000;67(3):214-26. [pmid: 10828907].
5 New Drug Application & Biologic License Application Efficacy Supplements (Approved CY 2008). [Internet] c2008 [cited 2012 January]. http://www.fda.gov/downloads/Drugs/DevelopmentApprovalProcess/HowDrugsareDevelopedandApproved/DrugandBiologicApprovalReports/EfficacySupplementApprovals/UCM081900.pdf.
6 Hutfless S, Almashat S, Berger Z, et al. Comparative Effectiveness and Safety of Pharmacologic Therapies for the Management of Crohn's Disease. Comparative Effectiveness Review No. 131. (Prepared by the Johns Hokins University Evidence-based Practice Center under Contract No. 290-2007-10061.) AHRQ Publication No. 14-EHC012-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
7 Cheifetz AS, Melmed GY, Spiegel B, et al. Setting priorities for comparative effectiveness research in inflammatory bowel disease: Results of an international provider survey, expert rand panel, and patient focus groups. Inflamm Bowel Dis. 2012;18(12):2294-30. [pmid: 22337359].
8 Initial national priorities for comparative effectiveness research. National Academies Press: National Academies Press. 2009.
9 AGA policy statement on comparative effectiveness research. American Gastroenterological Association. 2010.
10 Higgins PDR. Mucosal healing is not ready to be the primary endpoint. American Gastroenterological Association. 2010.
11 Siegel CA. Mucosal healing should be a primary endpoint. american gastroenterological association. American Gastroenterological Association. 2010.
12 Schnitzler F, Fidder H, Ferrante M, et al. Mucosal healing predicts long-term outcome of maintenance therapy with infliximab in crohn's disease. Inflamm Bowel Dis. 2009;15(9):1295-301. [pmid: 19340881].
13 Casellas F, Barreiro de Acosta M, et al. Mucosal healing restores normal health and quality of life in patients with inflammatory bowel disease. Eur J Gastroenterol Hepatol. 2012. Apr. 17. [pmid: 22517240].
14 Schreiber S, Colombel JF, Bloomfield R, et al. Increased response and remission rates in short-duration crohn's disease with subcutaneous certolizumab pegol: An analysis of PRECiSE 2 randomized maintenance trial data. Am J Gastroenterol. 2010;105(7):1574-82. [pmid: 20234346].
15 Santaguida P. McMaster quality assessment scale of harms (McHarm) for primary studies.
16 D'Haens G, Baert F, van Assche G, et al. Early combined immunosuppression or conventional management in patients with newly diagnosed crohn's disease: an open randomised trial. Lancet. 2008;371(9613):660-7. [pmid: 18295023].
17 Sostegni R, Daperno M, Scaglione N, et al. Review article: Crohn's disease: monitoring disease activity. Aliment Pharmacol Ther. Jun. Suppl 2. 2003;17:11-7. [pmid: 12786607].
18 Cellier C, Sahmoud T, Froguel E, et al. Correlations between clinical activity, endoscopic severity, and biological parameters in colonic or ileocolonic crohn's disease. A prospective multicentre study of 121 cases. the groupe d'etudes therapeutiques des affections inflammatoires digestives. Gut. 1994;35(2):231-5. [pmid: 7508411].
19 Fredd S. Standards for approval of new drugs for IBD. Inflamm Bowel Dis. 1995;1(4):284-94. [pmid: 23282428].
20 Talley NJ, Abreu MT, Achkar JP, et al. An evidence-based systematic review on medical therapies for inflammatory bowel disease. Am J Gastroenterol. Apr. Suppl 1. 2011;106:S2. 25. quiz S26. [pmid: 21472012].