# Methods

## Identification of Evidence Gaps

### Phase 1

We developed an analytic framework (Figure 1) to identify potential populations, medication comparisons and outcomes gaps from 2011 evidence report. We then searched the results and discussion sections of the evidence report, using the analytic framework, to identify potential research gaps. A Web-based assessment tool was populated with the identified research gaps specific to the induction of remission and the maintenance of remission. For each research gap category, an optional, free-text field was provided for stakeholders to identify gaps not listed in the assessment tool.

### Phase 2

The stakeholders were provided with a copy of the executive summary of the 2011 evidence report and were asked to independently identify the three highest priority populations, medication comparisons, and outcomes for future research for both induction of remission and maintenance of remission.

### Phase 3

Feedback from phase 2 was compiled and analyzed for agreement. Categories that did not achieve consensus on three or more options were sent back to the stakeholders in an attempt to build consensus. Compiled stakeholder responses regarding medication comparisons from phase 2 were sent to the stakeholders with a request to evaluate and prioritize the medication comparisons that did not achieve consensus.

## Criteria for Prioritization

The stakeholders were provided with a copy of the executive summary of the 2012 evidence report and were asked to independently identify the highest priority populations, medications, medication comparisons, and outcomes for future research for individuals with Crohn's disease.

## Engagement of Stakeholders, Researchers, and Funders

### Stakeholder Identification

We solicited recommendations from the American College of Gastroenterology (ACG), the American Gastroenterological Association (AGA), and the Crohn's and Colitis Foundation of America (CCFA) for expert stakeholders representative of clinicians, researchers, private and federal agencies, and patients. Nine experts in the field of Crohn's disease were identified and invited to serve as a stakeholder. Five academic physicians in the field of gastroenterology with a research interest in Crohn's disease management and one patient agreed to serve as stakeholders for this project.

### Stakeholder Engagement

We used a modified Delphi method to identify and prioritize existing gaps in the published literature as it pertains to the pharmacologic management of Crohn's disease, using seven steps across four phases (Figure 2). The Delphi method involves iterative rounds of responses by group members, providing aggregated feedback about other members' responses until consensus is reached. For each round, we used a Web-based assessment tool (SurveyMonkey™, Palo Alto, CA), with the list of the research gaps. Consensus among stakeholders was defined as agreement in responses of 50 percent or higher in three or more options for each category of future research needs. Categories that did not achieve 50 percent or greater consensus among the stakeholders on three or more options in phase 2 were returned for the stakeholders, with their compiled feedback from phase 2, to reprioritize.

Figure 2 Outline of steps for identification and prioritization of future research needs in Crohn's disease management

Figure 2 outlines the key steps for identification and prioritization of future research needs in Crohn's disease management. Step 1: identification of stakeholders; Phase 1, Step 2: Develop analytic framework to identify potential research gaps; Phase 1, Step 3: Identification of potential research gaps in the existing literature; Phase 2, Step 4: engage stakeholders to prioritize research gaps identified; Phase 3, Step 5: Engage stakeholders to re-prioritize research gaps identified; Phase 4, Step 6: Develop research questions based on stakeholder feedback; Phase 4, Step 7: engage stakeholders to evaluate and prioritize research questions.

## Research Question Development and Research Design Considerations

Research questions were developed based on feedback from stakeholders that achieved consensus during the second and third rounds. The stakeholders were presented with their compiled feedback from the second and third phases along with the research questions developed. They were asked to provide feedback on the clarity, utility, study design feasibility, and priority of the research questions.