# Acknowledgments

The Johns Hopkins University Evidence-based Practice Center thank the other authors of the 2013 evidence review on Crohn's disease, stakeholders for the Johns Hopkins University, and stakeholders external to the Johns Hopkins University (each listed below).

## Contributors

- Melvin Heyman, M.D.
  University of California, San Francisco School of Medicine
  San Francisco, CA
- Sunanda V. Kane, M.D.
  Mayo Clinic
  Rochester, MN
- Miguel Regueiro, M.D.
  University of Pittsburgh School of Medicine
  Pittsburgh, PA
- David T. Rubin, M.D.
  University of Chicago School of Medicine
  Chicago, IL
- Logan R. Thornton, M.P.H.
  Patient Stakeholder
- Thomas Ullman, M.D.
  Mt. Sinai Hospital
  New York, NY