# Discussion

The stakeholders identified future head-to-head research of combination therapy of TNF-alpha inhibitors and thiopurine against monotherapy of a TNF-alpha inhibitor for the maintenance of remission in Crohn's disease as a high priority. Based on stakeholder feedback, it is clear that combination therapy of a TNF-alpha inhibitor and thiopurine for maintenance of remission is extremely important for future research; however, there is some ambiguity regarding the monotherapy comparison as thiopurine did achieve our criterion for consensus in the first round (50%) but failed to do so in the second round (33%). However, this intervention was given highest priority by our group of stakeholders.

All stakeholders indicated that future research was needed for the induction of remission using monotherapy of one TNF-alpha inhibitor against another TNF-alpha inhibitor. Equally so, this intervention was given second highest priority by the stakeholders among the research questions developed.

Children were unanimously considered a high priority for all future research in the field of Crohn's disease. It was noted by one stakeholder that when assessing outcomes for children, the Pediatric CDAI should be used. It was agreed that the outcomes of highest priority are mucosal healing, patient reported outcomes, CDAI, and steroid reduction for bothinduction and maintenance of remission of Crohn's disease.

In a recent report, Cheifetz and colleagues engaged gastroenterologists to prioritize future comparative effectiveness research topics in inflammatory bowel disease. The authors reported that an “anti-TNF agent alone versus anti-TNF agent with thiopurine in patients with moderate to severe Crohn's disease failing thiopurine” was their sixth highest research priority among all inflammatory bowel disease related research questions. In addition, they reported that the “efficacy and safety of long-term immunomodulation versus anti-TNF therapy in Crohn's disease…” was their eighth highest research priority. Likewise, their findings reported the need to accept mucosal healing as a primary outcome.7 These results support our findings of high priority interventions and outcomes for future research; however, our stakeholders unanimously agreed that children are the highest priority for future research while Cheifetz identified adults as a higher priority.

There were a few limitations to this study. The investigators on the original systematic review were actively involved in the identification of research gaps in this study which allowed for potential experimenter bias. This was mitigated by allowing stakeholders to independently identify other populations, medication comparisons or outcomes for future research during each phase. In addition, the complexity of the concepts in this topic may be a barrier for patient stakeholders to contribute however our patient stakeholder is a certified health educator for this topic and possessed the requisite clinical knowledge to provide meaningful feedback.

The American Recovery and Reinvestment Act of 2009 outlined several research priorities specific to the treatment of Crohn's disease8 that have been endorsed by the AGA9 including the introduction of biologics into the treatment algorithm for inflammatory diseases, including Crohn's disease. With respect to outcomes of interest, there are still conflicting opinions within AGA regarding the utility of mucosal healing as a primary endpoint.10, 11 Despite these recent conflicts, it is clear from our findings and other recent reports,7, 12, 13 that mucosal healing should be considered as a primary endpoint.