# Conclusion

Children are a high priority for future research for the induction and maintenance of remission in patients diagnosed with Crohn's disease. Stakeholders identified a substantial need for further research on the use of TNF-alpha inhibitors for induction and maintenance of remission of Crohn's disease. The stakeholders also identified an important need to report outcomes of mucosal healing, patient reported outcomes, CDAI, and steroid reduction when conducting induction and maintenance of remission trials for Crohn's disease.