# Background

## Context

Crohn's disease is characterized by chronic inflammation that can occur anywhere in the gastrointestinal tract, but most often affects the small bowel and colon. Typical symptoms include abdominal pain, chronic diarrhea, and gastrointestinal bleeding. Crohn's disease affects between 400,000 and 600,000 North Americans.1 Ten percent of Crohn's disease patients are children under the age of 17 years.2

The clinical management of Crohn's disease is complicated. Clinical practice guidelines for Crohn's disease recommend that clinicians take into account the disease location, severity, complications, and extra-intestinal manifestations when choosing a treatment strategy. However, no universal treatment strategy exists for patients.3 The lack of consensus about the best treatment strategy can result in confusion and frustration for the Crohn's disease patient as well as healthcare providers.

Medications are the healthcare providers' preferred treatment for Crohn's disease with surgical interventions reserved for refractory disease or evidence of dysplasia. Medical therapy in Crohn's disease targets intestinal inflammation with the intent of altering the natural history of the disease. Corticosteroids and aminosalicylates, such as sulfasalazine, have been used since the 1950s. Immunomodulators (6-mercaptopurine, azathioprine, and methotrexate) have been used for the treatment of Crohn's disease since the 1970s, although the use of these medications was not routine until the 1990s.4 The first biologic tumor necrosis factor (TNF)-alpha inhibitor, infliximab, was approved by the Food and Drug Administration (FDA) for the treatment of Crohn's disease in adults in 1998. The FDA-approved monoclonal antibodies against TNF-alpha inhibitor also include adalimumab and certolizumab pegol.5 Other biologic agents used for the treatment of Crohn's disease include natalizumab, a monoclonal antibody against cellular adhesion molecule α4-integrin that is FDA-approved for Crohn's disease in adults5, and ustekinumab, a monoclonal antibody against interleukin 12 and interleukin 23 that is not currently FDA-approved for Crohn's disease.

Our recent systematic review addressed several Key Questions in the management of Crohn's disease.6 In that review, we identified several important gaps in the evidence, as shown in the analytic framework depicted in Figure 1 and described in further detail below. The objective of this report is to identify and prioritize existing gaps in the synthesized literature pertaining to pharmacological induction and maintenance of remission for patients diagnosed with Crohn's disease by engaging expert stakeholders using a modified Delphi method.

Figure 1 Analytic framework for identification of potential research gaps in phase 1

Figure 1 illustrates the analytic framework for identification of potential research gaps. The framework identifies possible gaps in the research that has been done in adults and/or children with Crohn's disease. The figure includes a list of gaps regarding treatment of active Crohn's disease to achieve remission, and a list for treatment of patients in remission for the purpose of maintaining remission.

## Evidence Gaps

We used the PICOTS framework to identify gaps in how the evidence addressed the populations, interventions, comparisons, outcomes, timing, and setting of interest (see Figure 1). Several gaps related to the target population (children, non-white, and risk stratification based on patient characteristics). Other gaps related to interventions and comparisons of interest (step up versus top down treatment, and head to head comparisons within and between treatment classes), outcomes of interest (mucosal healing, and patient-reported symptoms), or a timing issue (i.e., remission beyond 2 years). These gaps served as the foundation to identify future research needs. In the following section, we elaborate further on the research gaps identified in the comparative effectiveness review.

### Populations

Few pediatric studies were identified. Nine studies were identified that included exclusively pediatric patients. None of the adult studies that allowed participants under age 18 reported the results for children separately. Given the paucity of trials or observational studies that reported on safety, there is little evidence to guide the most effective and safe treatment for children. There is no existing evidence of quality of life or other patient-reported outcomes for these medications as reported by children or their parents.

Few studies included patients with complicated and severe disease. Many modern randomized controlled trials (RCTs) apply only to patients with uncomplicated, luminal Crohn's disease without stricture or abscess as these patients were excluded from the trials. Additionally, many RCTs excluded patients with very severe disease (Crohn's disease activity index [CDAI] > 450). Only two RCTs aimed to examine patients with fistula exclusively. The observational studies tended to include patients with all patterns of disease activity or behavior. Although the observational study findings are applicable to a wider range of patients, the majority of evidence was graded as low or insufficient. Because the risk-benefit ratio of medication use may depend on severity of disease, both effectiveness and safety should be assessed by disease severity.

Studies of recently diagnosed patients are needed because medication effectiveness may differ by disease duration. Most RCTs included patients with longer disease duration, often greater than ten years. Only a few studies randomized patients within three years of diagnosis. There are preliminary subgroup data that show patients with a short duration of disease have better response and remission rates.14

Additional future research needs include: (a) the inclusion of non-white patients in RCTs and safety studies; (b) performing head to head comparisons, especially for the biologics where no head-to-head study was identified; (c) performing head-to-head trials of biologics and immunomodulators that allow all thiopurine methyltransferase (TPMT) phenotypes, because the rate of TPMT metabolism rarely prohibits treatment in the clinical setting; (d) identifying treatments to induce and maintain remission in patients who do not respond to biologics, as these patients were excluded from many of the biologic maintenance trials; (e) specifying safety outcomes in advance and including them as primary or secondary outcomes in RCTs; (f) clarify whether safety outcomes associated with medication efficacy (such as disease flare and abscess) are safety outcomes or efficacy outcomes; (g) clearly accounting for the use of other medications in both RCTs and observational studies so that the independent effect of the medication of interest is more clear; (h) accounting for other confounders in observational studies and examining the reasons for the imbalance of potential confounders in the setting of RCTs; (i) conducting and reporting subgroup analyses appropriately in pre-specified groups and using interaction terms; (j) consistent reporting of outcomes in text and figures, especially for clinically relevant time points other than the primary outcome time point; and (k) for extremely rare safety outcomes that are likely to be reported in case reports, such as progressive multifocal leukoencephalopathy or hepatospenic T-cell lymphoma, synthesizing the data on a potential causal relationship would be more efficient if case reports emphasized criteria used to estimate these causal relationships such as the McMaster Quality Assessment Scale of Harms.15

### Interventions

Comparative effectiveness studies of the step-up versus top-down approach are needed. The step-up versus top-down approach for treatment was one of the controversies that prompted this report. We also chose to organize our report according to the top-down approach to provide relevance to this controversy. However, only one small open-label study directly tested step-up versus top-down treatment. Because patients were allowed to step-up throughout the study, by week 52, 20 percent of all patients were receiving infliximab, regardless of which group they were originally randomized, and by week 78 fewer than 10 percent of all patients were receiving prednisolone.16 We had hoped to perform indirect comparisons in the absence of direct comparisons of step-up versus top-down treatment. However, we were not able to perform these indirect comparisons due to the heterogeneity of the study designs as described in the limitations.

### Outcomes

RCTs did not routinely report on outcomes other than disease activity scales. Few studies reported on other indications of clinical remission such as hospitalizations, surgeries or mucosal healing. Controversy exists over the clinical relevance of the widely used CDAI as a measure of clinical disease activity and the CDAI is not considered an accurate measure of disease activity in stricturing or fistulizing disease.17 The CDAI also does not correlate well with mucosal healing.18 Additionally, disease activity indices are difficult to calculate and are not practical in the clinical setting,17 limiting the applicability of the remission findings to clinical practice. Even though a representative from the FDA reported in 1995 that induction and maintenance of remission in Crohn's disease should include both absence of symptoms and endoscopic evidence of healing, few studies reported on mucosal healing.19 There was information on the patient-reported Inflammatory Bowel Disease Questionnaire (IBDQ) outcome measure and occasionally the Medical Outcome Study Short Form (SF-36), but not days of work or school missed, which may be more meaningful and easier to communicate to Crohn's disease patients.

One study reported on a patient-reported outcome after surgical resection. Given that patient-reported outcomes may be even more relevant to patients who are not currently experiencing active clinical or endoscopic disease, these outcomes may be most relevant for treatment choice in these patients.

### Timing

Evidence is lacking on the optimal treatment of Crohn's disease over a number of years. The short duration of the RCTs and observational studies limits the ability to assess one or more medications over a sizeable portion of a person's lifetime with disease. The duration of time that a treatment works, particularly for maintaining remission, is especially relevant for children who may not be fully developed and have a lifetime of disease and its treatment ahead of them.

### Study Design

Observational studies may be too short in duration to observe some safety outcomes. The rare safety outcomes may take years to develop after exposure to the medication or may take years of medication use to develop. The majority of observational studies were shorter than five years,20 which may not be sufficient to observe cases caused by the use of medication recorded during the study time period.