# Search Strategies and Potentially Relevant Ongoing/Recently Completed Studies

Table A-1 Search Strategies for potentially relevant ongoing studies for pharmacological management of Crohn's disease

Resource | Search Parameters | Search Terms/Strategy
URL | Search Parameters | Search Terms/Strategy
ClinicalTrials.gov http://clinicaltrials.gov/ | Advanced search, Conditions field used | Pharmacological Management of Crohn's Disease OR Treatment of Crohn's Disease
EU Clinical Trials Register https://www.clinicaltrialsregister.eu/ | Not applicable | Crohn's Disease
NIH Reporter http://projectreporter.nih.gov/reporter.cfm | Projects field searched | Pharmacological Management of Crohn's Disease OR Treatment of Crohn's Disease
Canadian Institutes of Health Research http://www.cihr-irsc.gc.ca/ | Funding Decisions Data field searched | Pharmacological Management of Crohn's Disease OR Treatment of Crohn's Disease
World Health Organization International Clinical Trials Registry Platform Search Portal http://apps.who.int/trialsearch/ | Searched Condition field, Recruitment status = ALL | Pharmacological Management of Crohn's Disease OR Treatment of Crohn's Disease

Table A-2 Potentially relevant ongoing/recently completed studies

Title/ Identifier(s) | Study Dates | Description | Sponsor or Principal Investigator Collaborator(s) | Source
Title: Safety Study of Entocort for Children With Crohn's Disease Identifier(s): NCT01444092 | Start date: November 2011 Estimated study completion date: January 2014 Estimated primary completion date: January 2014 (Final data collection date for primary outcome measure) | Purpose: A Safety Study using Entocort EC for children with mild to moderate Crohn's Disease Study design: Endpoint Classification: Safety Study Intervention Model: Single Group Assignment Masking: Open Label Primary Purpose: Treatment Condition(s): Crohn's Disease Intervention(s): Drug: Entocort Estimated enrollment: 110 | Sponsor OR PI and Collaborator(s): AstraZeneca | ClinicalTrials.gov Accessed at: http://clinicaltrials.gov/ct2/show/NCT01444092
Title: Cimzia Versus Mesalamine for Crohn's Recurrence Identifier(s): NCT01696942 | Start date: December 2012 Estimated study completion date: December 2015 Estimated primary completion date: December 2014 (Final data collection date for primary outcome measure) | Purpose: To evaluate the difference in clinical recurrence rates between certolizumab and mesalamine after 4 weeks, 3 months, 6 months, 9 months, and 12 months of use following ileocolectomy for Crohn's disease using the Crohn's Disease Activity Index (CDAI). Study design: Allocation: Randomized Endpoint Classification: Efficacy Study Intervention Model: Parallel Assignment Masking: Open Label Primary Purpose: Treatment Condition(s): Crohn's Disease Intervention(s): Drug: Cimzia Drug: Mesalamine Estimated enrollment: 24 | Sponsor OR PI and Collaborator(s): Milton S. Hershey Medical Center UCB, Inc. | ClinicalTrials.gov Accessed at: http://clinicaltrials.gov/ct2/show/NCT01696942
Title: EUS Evaluation of Perianal and Peri-rectal Fistulizing Crohn's Disease With CERTOLIZUMAB Treatment Identifier(s): NCT01582568 | Start date: June 2011 Estimated study completion date: December 2013 Estimated primary completion date: December 2013 (Final data collection date for primary outcome measure) | Purpose: To assess perianal and perirectal fistula healing (complete closure) based on endoscopic ultrasound (EUS) evaluation at 3 months and by PDAI (Pouchitis Disease Activity Index) and Fistula Drainage assessment by 6 months, showing no fistula (new or recurrence) in treatment of Crohn's' disease patient with Certolizumab (Cimzia). Study design: Endpoint Classification: Efficacy Study Intervention Model: Single Group Assignment Masking: Open Label Primary Purpose: Treatment Condition(s): Crohns Disease Intervention(s): Drug: Certolizumab Estimated enrollment: 20 | Sponsor OR PI and Collaborator(s): Baylor College of Medicine UCB, Inc. | ClinicalTrials.gov Accessed at: http://clinicaltrials.gov/ct2/show/NCT01582568
Title: Efficacy and Safety of Two Treatment Models in Subjects With Moderate to Severe Crohn's Disease (CALM) Identifier(s): NCT01235689 | Start date: February 2011 Estimated study completion date: June 2014 Estimated primary completion date: June 2014 (Final data collection date for primary outcome measure) | Purpose: To evaluate the Efficacy and Safety of two treatment models in subjects with moderate to severe Crohn's Disease Study design: Allocation: Randomized Endpoint Classification: Safety/Efficacy Study Intervention Model: Parallel Assignment Masking: Open Label Primary Purpose: Treatment Condition(s): Crohn's Disease Intervention(s): Biological: adalimumab Drug: prednisone Drug: azathioprine Estimated enrollment: 240 | Sponsor OR PI and Collaborator(s): Abbott | ClinicalTrials.gov Accessed at: http://clinicaltrials.gov/ct2/show/NCT01235689
Title: Adalimumab for the Management of Post-operative Crohn's Disease (CD) (POPART) Identifier(s): NCT01629628 | Start date: July 2012 Estimated study completion date: July 2016 Estimated primary completion date: July 2016 (Final data collection date for primary outcome measure) | Purpose: Comparing the efficacy of adalimumab with immunomodulator therapy (i.e. 6-mercaptopurine, 6-MP), in maintaining remission of post-operative CD patients, with a high risk of disease recurrence. Study design: Allocation: Randomized Endpoint Classification: Efficacy Study Intervention Model: Parallel Assignment Masking: Open Label Primary Purpose: Prevention Condition(s): Crohn Disease Intervention(s): Drug: Adalimumab Drug: 6 Mercaptopurine Estimated enrollment: | Sponsor OR PI and Collaborator(s): Tel-Aviv Sourasky Medical Center Abbott | ClinicalTrials.gov Accessed at: http://clinicaltrials.gov/ct2/show/NCT01629628
Title: Comparison of the human TNF-alpha antibody adalimumab with infliximab in induction and maintenance of steroid-free remission in patients with moderate to severe Crohn's disease Identifier(s): EudraCT Number: 2008-004926-18 | Start date: 2008-10-30 Estimated study completion date: Ongoing | Purpose: To compare the human TNF-alpha antibody adalimumab with infliximab in respect to induction and maintenance of steroid-free remission in patients with moderate to severe Crohn's disease Study design: RCT Condition(s): Moderate to severe Crohn's disease Intervention(s): Adalimumab Infliximab Estimated enrollment: 100 | Sponsor OR PI and Collaborator(s): IBD Center LMU Munich | EU Clinical Trials Register Accessed at: https://www.clinicaltrialsregister.eu/ctr-search/trial/2008-004926-18/DE