# Acronyms and Abbreviations

ACG: American College of Gastroenterology
AGA: American Gastroenterological Association
AHRQ: Agency for Healthcare Research and Quality
CCFA: Crohn's and Colitis Foundation of America
CDAI: Crohn's Disease Activity Index
EPC: Evidence-based Practice Center
FDA: Food and Drug Administration
PICOTS: Populations, interventions, comparisons, outcomes, timing, and setting of interest
RCT: Randomized controlled trial
TNF: Tumor necrosis factor
TPMT: Thiopurine methyltransferase