# Results

## Research Needs

Of 11 stakeholders who were invited, 10 participated in the teleconferences, and 9 participated in the prioritization process. The FRN identification process led to the nomination of 12 topics (Table 3). The three topics with the highest number of stakeholder endorsements constitute the highest priority FRN topics. Two topics (one on the use of intravascular physiologic measurements like FFR in treatment decisionmaking before stenting; one on the impact of the use of intravascular imaging diagnostics on stenting) are based directly on evidence gaps identified in the CER. These two topics are of interest because FFR and IVUS have not been thoroughly studied. There is only one trial comparing FFR with angiography alone to assess the use of FFR to help determine which patients should receive stents. Similarly, there is a lack of data on the use of IVUS, as compared with angiography alone, to evaluate placement of newer types of stents including bioabsorbable ones. The third topic on the added value of intravascular diagnostic techniques in patients for whom there is already a clear clinical or other noninvasive diagnostic indicator (e.g., a high-risk positive stress perfusion scan, a noninvasive imaging technique that demonstrated large areas of decreased blood flow in the heart) for the potential need for revascularization was raised by the stakeholders.

Table 3 Prioritized topics for future research needs in intravascular diagnostics, compared with angiography alone

Topic^*^ | Topic Questions | Number of Stakeholders Who Think This Is a High-Priority Topic | Mean
Prioritized Future Research Needs Topics
1 | What is the impact on clinical outcomes of a treatment decision (medical therapy, stent, or bypass) made on the basis of the adjunctive use of intravascular physiologic diagnostics, as compared with angiography alone? | 7 | 4.67
2 | In patients in whom there is already a precatheterization indication for stenting, what is the impact on stenting parameters (e.g., which lesion to stent, type of stent, stent length) and clinical outcomes of the use versus non-use of intravascular diagnostics? | 6 | 4.44
3 | Once the decision has been made to place a stent, what is the impact on clinical outcomes of the adjunctive use of intravascular imaging diagnostics, such as IVUS or OCT, in stent placement and stent optimization, as compared with angiography alone? | 5 | 4.22
Other Topics
4 | What is the impact on clinical outcomes of a treatment decision (medical therapy, stent, or bypass) made on the basis of the adjunctive use of intravascular imaging diagnostics, such as IVUS or OCT, as compared with angiography alone? | 4 | 4.11
5 | What is the impact on clinical outcomes of operator experience, as measured by the number of completed procedures in using intravascular diagnostics? | 4 | 3.78
6 | What is the impact of baseline characteristics (e.g., sex, age, co-morbidities, type of lesions, severity of disease) on clinical outcomes when using intravascular diagnostics during coronary stenting, as compared with angiography alone? | 4 | 4.00
7 | What is the impact on clinical outcomes of a treatment decision (medical therapy, stent, or bypass) made on the basis of the adjunctive use of intravascular physiologic diagnostics, as compared with other intravascular diagnostics? | 3 | 3.67
8 | What is the impact on clinical outcomes of a treatment decision (medical therapy, stent, or bypass) made on the basis of the adjunctive use of intravascular imaging diagnostics, such as IVUS or OCT, as compared with FFR? | 3 | 3.67
9 | What adverse events and complications have been associated with the use of intravascular diagnostic procedures for coronary stenting, as compared with angiography alone? | 2 | 3.44
10 | Once the decision has been made to place a stent, what is the impact on clinical outcomes of the adjunctive use of intravascular imaging diagnostics, such as IVUS or OCT, during stenting and stent optimization, as compared with other intravascular diagnostics such as FFR? | 2 | 3.22
11 | What is the impact on clinical outcomes of the adjunctive use of new and on-the-horizon or hybrid intravascular diagnostics, as compared with angiography alone or other established techniques such as FFR or IVUS? | 2 | 3.33
12 | What is the impact on therapeutic decisionmaking and clinical outcomes of the use of intravascular diagnostics in patients who were discovered to have no evidence of coronary artery disease by angiography (such as in patients examined due to intense coronary vasospasm)? | 2 | 3

Abbreviations: FFR = fractional flow reserve; IVUS = intravascular ultrasound; OCT = optical coherence tomograph

* Prioritized topics (1–12) are listed in the order they were prioritized by the stakeholder panel.

### High-Priority Future Research Needs Topic 1

What is the impact on clinical outcomes of a treatment decision (medical therapy, stent, or bypass) made on the basis of the adjunctive use of intravascular physiologic diagnostics, as compared with angiography alone?

#### Background

The CER evaluating intravascular diagnostic techniques identified evidence gaps pertaining to the use of these diagnostic techniques in diagnosing, assessing, and triaging patients with suspected CAD to appropriate therapeutic modalities (medical therapy, stent, or bypass). Only one trial rated as being low risk of bias compared the adjunctive use of intravascular physiologic diagnostics (FFR) versus angiography alone during stenting.41 Although the evidence was rated to be of moderate strength, the stakeholders felt more research was needed for a number of reasons. First, as evidence currently rests primarily on one randomized controlled trial (RCT) there is the possibility that future studies will not support the favorable effect of FFR-guided stenting; this phenomenon, an initial effect that eventually dissipates through subsequent studies, has been well documented.44 Second, given the widespread use of stents (with associated harms and costs) and the well documented variation in practice, any technology that can better target risks and benefits could have a major impact on patient outcomes and healthcare costs. As such it is important to fully explore dimensions beyond what is covered in existing trials. These include whether FFR should be applied to diagnose patients with suspected CAD and triage them to different therapeutic modalities (medical therapy, stent, or bypass) based on the results of intravascular physiologic diagnostics^e^, how they apply to patients with borderline or intermediate lesions and other subgroups such as women (especially regarding the dilemma of non-obstructive CAD) and those with significant comorbidities, and how to use intravascular physiologic diagnostics to better characterize angiographic markers.41,44

e The recently published FAME II trial [NEJM 2012; 367:991-1001] suggests patients with stable CAD might benefit from the use of FFR. This trial did not have an angiography alone arm.

#### Proposed Study Design

We propose a prospective observational study design, using a combination of catheterization registry data that are derived directly from electronic health records, linked with Medicare claims and state mortality records. Treatment assignment would be non-random, but statistical techniques could be used to adjust for potential confounding from treatment selection.

#### Value of Study Design

Even though an RCT comparing the use versus nonuse of FFR-guided angiography could help clarify the value of additional information from intravascular diagnostic to help determine which patients would benefit from optimal medical therapy, stent, or bypass graft, such an RCT may be difficult to conduct as FFR-guided PCI is fast-becoming the standard of care in patients with borderline and intermediate lesions (personal communication from M. Brennan).

While observational studies can compare outcomes of treatment decision made on the basis of FFR versus no FFR, they are subject to biases due to the lack of randomization. Established methodological approaches such as matching and regression analysis, including propensity score analyses, may be used to reduce biases from known imbalances at baseline. In addition, sensitivity analyses may be used to explore the robustness of findings for nonrandomized comparisons. However, the use of FFR depends on provider preference, which is subject to complex and difficult to measure factors. Thus, findings gleaned from cohort studies should be considered as hypothesis-generating rather than confirmatory.

On the other hand, observational studies have the benefit of wider generalizability when data collection occurs in real-life clinical settings and without restrictive inclusion criteria.

#### Ability To Recruit

There should be no barriers to recruitment for observational studies addressing the use of FFR.

#### Resource Use, Size, and Duration

The reliance on observational data substantially reduces resource use and increases feasibility in addressing this evidence gap. Post hoc analyses of existing observational studies can be done quickly and with modest resources. Generally, given the ease of retrospective data analysis, care should be taken to avoid biases from exploratory data-mining. Large databases like the National Cardiovascular Data Registry (NCDR) CathPCI Registry could be linked to Centers for Medicare and Medicaid (CMS) claims data;45 this would provide data for comparative analyses of patients who had FFR versus those who had not.

Prospective observational studies allow for purposeful planning to answer hypotheses and more complete collection of relevant data, which can increase validity compared with post hoc observational studies using existing data. However, prospective planning and data collection consume a greater amount of resources.

#### Ethical Issues

There should be no ethical barriers to the analysis of existing databases or to conducting prospective trials in the investigation of this evidence gap. Patient confidentiality is assumed.

### High-Priority Future Research Needs Topic 2

In patients with clinical or other indicators suggesting the potential need for revascularization (stenting or coronary bypass graft), even before the catheterization results are known, what is the impact on treatment decision (e.g., whether to stent); and stenting parameters (e.g., which lesion to stent, type of stent, stent length) of the use versus nonuse of intravascular diagnostics should the patients eventually undergo stenting? What is the impact on clinical outcomes?

2A. In patients with a high-risk positive stress perfusion scan (e.g., large areas of no or hypoperfusion in the myocardium), what is the impact on stenting parameters (e.g., which lesion to stent, type of stent, stent length) and clinical outcomes of the use versus nonuse of intravascular diagnostics if the patients undergo stenting?

2B. In patients with a negative stress perfusion scan but other precatheterization indicator like classic symptom complex suggesting the potential need for revascularization (stenting or coronary artery bypass graft), what is the impact on the decision to stent and clinical outcomes of the use versus non-use of intravascular diagnostics?

#### Background

The stakeholders raised the issue of the additional value of adjunctive intravascular diagnostic techniques in patients who already have either clinical or non-invasive diagnostic indication (e.g., high-risk positive stress perfusion scan) for undergoing stenting procedures or coronary artery bypass grafts. For those patients who are selected for stenting, one can hypothesize that additional information provided by intravascular diagnostics can aid in the selection of the type of stent, stent length, and other parameters in stent deployment. Our CER did not identify this as an evidence gap because our CER did not focus on this particular population. In addition, our CER evaluated the role of intravascular diagnostics only on the number of stents utilized and stent dilatation, but did not evaluate the role of intravascular diagnostics on the selection of the type of stent or stent length and how these choices impact clinical outcomes. This topic was further refined post survey into two subquestions 2A and 2B (see above) with the help of domain experts.

#### Proposed Study Designs

We propose both a prospective randomized controlled study and an observational study design. For this topic, our key informants informed us that FFR, a physiologic measurement, is primarily used in the determination of whether and which lesion to stent; while IVUS, an imaging technique, can aid in determining stent parameters like stent inflation pressure, stent length, and others. Accordingly, a pragmatic RCT can compare the use versus nonuse of IVUS in patients with a high-risk positive stress test, but an RCT comparing the use versus non-use of FFR-guided angiography may be difficult to conduct as FFR-guided PCI is fast-becoming the standard of care. We also propose a prospective observational study design, using a combination of catheterization registry data that are derived directly from electronic health records, linked with Medicare claims and state mortality records. Treatment assignment would be non-random, but statistical techniques could be used to adjust for potential confounding from treatment selection.

##### Randomized Controlled Trials

###### Value of Study Design

RCTs provide the most rigorous study design for examining comparative effectiveness for clinical outcomes. RCTs comparing the use of IVUS versus angiography alone on stenting parameters and clinical outcomes would help to fill in the evidence gaps. As it is unclear whether the real-world application will have similar results as RCT, trials should be pragmatic, with wide eligibility criteria and diverse settings. A reasonable time-frame for such studies would be 1 year or more. For a trial of IVUS versus no IVUS in patients with high-risk stress test results, it should be noted that medical therapy alone could still be a treatment option (in addition to stenting or coronary bypass) in both randomized arms, as our domain experts explained that for some of these patients, medical therapy alone may be appropriate.

###### Resource Use, Size, and Duration

An RCT, especially one with a long duration and large sample size, is a highly resource-intensive endeavor. The decision to conduct such a trial must be balanced against the value of the information that can be gained from longer followup and wider representation. It may be reasonable to design an RCT based on infrastructure already in place to minimize cost. For example, a pragmatic trial could be designed using the CathPCI registry.

To estimate an appropriate trial sample size, we carried out a power calculation using standard formula for a two-sided chi-square test. We based our effect size estimates on the actual estimates reported by Russo and colleagues' trial of IVUS versus angiography alone in patients scheduled for elective stent placements.35 Assuming 1-year rates of target vessel revascularization (primary endpoint prespecified in the study) of 12 percent in the angiography group and 8 percent in the IVUS group, an alpha level of 0.05 and a statistical power of 0.80, a minimum sample size of 882 per group is required. As there was only a 7 percent attrition at 1 year for this trial, one could conservatively estimate loss to followup at no more than 5 to 10 percent with a diligent followup protocol. It should be noted that the Russo trial prespecified target vessel revascularization as the only primary endpoint. MACE is considered a secondary endpoint in this trial, estimates of which are similar and statistically nonsignificantly different between IVUS and angiography alone at 12 months (18.4 vs. 18.7 percent, respectively, P=0.93), suggesting powering our recommended trial based on patient outcomes from stenting may not be realistic.

###### Ability To Recruit

There could be barriers to recruitment for RCTs addressing this evidence gap as the use of intravascular diagnostics like IVUS gains wide acceptance.

###### Ethical Issues

As the use of the various intravascular diagnostic techniques becomes increasingly common in the community, there may not be a perceived equipoise to continue conducting trials of adjunctive intravascular diagnostics versus angiography alone despite the lack of studies demonstrating impact on patient outcomes.

##### Observational Studies

###### Value of Study Design

Observational studies could provide preliminary data comparing patients with negative stress test who had intravascular diagnostics versus those who had not. Depending on the results, there may be equipoise to justify an RCT in the future.

###### Ability to Recruit

There should be no barriers to recruitment for observational studies addressing the use of FFR and/or IVUS.

###### Resource Use, Size, and Duration

Once again, large databases like the National Cardiovascular Data Registry CathPCI Registry could be linked to Centers for Medicare and Medicaid (CMS) claims data;45 this would provide data for comparative analyses of patients with negative stress test who had FFR or IVUS versus those who had not. Other databases like Mass-DAC (www.massdac.org) and New York State Percutaneous Coronary Intervention Reporting System (www.health.ny.gov/statistics/diseases/cardiovascular/docs/pci_2006-2008.pdf) could also provide useful comparative data.

###### Ethical issues

There should be no ethical barriers to the analysis of existing databases or to conducting prospective trials in the investigation of this evidence gap. Patient confidentiality is assumed.

### High-Priority Future Research Needs Topic 3

Once the decision has been made to place a stent, what is the impact on clinical outcomes of the adjunctive use of intravascular imaging diagnostics, such as IVUS or optical coherence tomography (OCT), in stent placement and stent optimization, as compared with angiography alone?

#### Background

The CER evaluating intravascular imaging diagnostic techniques, such as IVUS or OCT, identified evidence gaps pertaining to the use of these diagnostic techniques in placement of newer stents and stent optimization, as compared with angiography. These newer stents can include drug-eluting stents, biodegradable stents, and others. Only two studies compared the adjunctive use of intravascular imaging diagnostics versus angiography alone during drug-eluting stent deployment.18,19 There were no studies evaluating the adjunctive use of OCT versus angiography alone during stenting. Therefore, it is currently uncertain whether these techniques are effective in stent placement of newer stents and stent optimization, as compared with angiography.

#### Proposed Study Designs

We propose both a prospective randomized controlled study and an observational study design.

##### Randomized Controlled Trials

###### Value of Study Design

RCTs provide the most rigorous study design for examining comparative effectiveness for clinical outcomes. RCTs comparing the use of intravascular diagnostics versus angiography alone on stenting parameters and clinical outcomes would help to fill in the evidence gaps. As it is unclear whether the real-world application will have similar results as RCT, trials should be pragmatic, with wide eligibility criteria and diverse settings. A reasonable time-frame for such studies would be 1 year or more.

###### Resource Use, Size, and Duration

An RCT, especially one with a long duration and large sample size, is a highly resource-intensive endeavor. The decision to conduct such a trial must be balanced against the value of the information that can be gained from longer followup and wider representation. It may be reasonable to design an RCT based on infrastructure already in place to minimize cost. For example, a pragmatic trial could be designed using the CathPCI registry.

To estimate an appropriate trial sample size, we carried out a power calculation using standard formula for a two-sided chi-square test. We based our effect size estimates on the FAME trial.41 Assuming 1-year rates of MACE of 18 percent in the angiography group and 13 percent in the FFR group, an alpha level of 0.05 and a statistical power of 0.80, a minimum sample size of 821 per group is required. As there was zero attrition at 1 year for the FAME trial, one could conservatively estimate loss to followup at no more than 5 to 10 percent with a diligent followup protocol.

###### Ability To Recruit

There could be barriers to recruitment for RCTs addressing this evidence gap as the use of intravascular diagnostics gains wide acceptance.

###### Ethical Issues

There may not be a perceived equipoise to continue conducting trials of adjunctive intravascular diagnostics versus angiography alone despite the lack of studies demonstrating impact on patient outcomes.

##### Observational Studies

###### Value of Study Design

Observational studies can compare outcomes of the use of intravascular diagnostics versus angiography alone. However, observational studies are subject to limitations described previously. However, the use of observational studies have the benefit of wider generalizability and likely to be a less costly proposition than an RCT.

###### Ability To Recruit

There should be no barriers to recruitment for observational studies addressing the use of intravascular diagnostics.

###### Resource Use, Size, and Duration

The reliance on observational data substantially reduces resource use and increases feasibility in addressing this evidence gap. However, existing registry like the CathPCI database does not have enough details to answer the questions concerning stenting parameters. A registry based on a collection of high volume centers specifically recording these details may have to be built de novo, thereby substantially increase the cost of this proposition. Alternatively, one could remunerate site investigators to pull and review cases to supplement details of interest to existing databases. For example, a novel module could be implemented in the CathPCI registry to collect additional IVUS parameters and additional stenting parameters. These data could be used to assess how IVUS influenced the procedure. This could be linked to the case file for the rest of the baseline and followup data and the non-IVUS PCI procedures from the registry could serve as the control.

###### Ethical Issues

There should be no ethical barriers to the analysis of existing databases or to conducting prospective trials in the investigation of this evidence gap. Patient confidentiality is assumed.