# References

1 Concannon TW, Meissner P, Grunbaum JA, et al. A new taxonomy for stakeholder engagement in patient-centered outcomes research. J Gen Intern Med. Aug. 2012;27(8):985-91. [pmid: 22528615].
2 Raman G. Intravascular Diagnostic Procedures and Imaging Techniques versus Angiography Alone: A Comparative Effectiveness Review. 2012.
3 Agostoni P, Valgimigli M, Van Mieghem CA, et al. Comparison of early outcome of percutaneous coronary intervention for unprotected left main coronary artery disease in the drug-eluting stent era with versus without intravascular ultrasonic guidance. American Journal of Cardiology. Mar. 1. 2005;95(5):644-47. [pmid: 15721110].
4 Ahmed K, Jeong MH, Chakraborty R, et al. Role of intravascular ultrasound in patients with acute myocardial infarction undergoing percutaneous coronary intervention. American Journal of Cardiology. 2011;108(1):8-14. Jul. 1. [pmid: 21529735].
5 Albiero R, Rau T, Schluter M, et al. Comparison of immediate and intermediate-term results of intravascular ultrasound versus angiography-guided Palmaz-Schatz stent implantation in matched lesions. Circulation. Nov. 4. 1997;96(9):2997-3005. [pmid: 9386168].
6 Biondi-Zoccai G, Sheiban I, Romagnoli E, et al. Is intravascular ultrasound beneficial for percutaneous coronary intervention of bifurcation lesions? Evidence from a 4,314-patient registry. Clinical Research in Cardiology. 2011;100(11):1021-8. Nov. [pmid: 21701872].
7 Blasini R, Neumann FJ, Schmitt C, et al. Restenosis rate after intravascular ultrasound-guided coronary stent implantation. Catheterization & Cardiovascular Diagnosis. Aug. 1998;44(4):380-86. [pmid: 9716200].
8 Choi JW, Goodreau LM, Davidson CJ. Resource utilization and clinical outcomes of coronary stenting: a comparison of intravascular ultrasound and angiographical guided stent implantation. American Heart Journal. Jul. 2001;142(1):112-18. [pmid: 11431666].
9 Claessen BE, Mehran R, Mintz GS, et al. Impact of intravascular ultrasound imaging on early and late clinical outcomes following percutaneous coronary intervention with drug-eluting stents. [Erratum appears in JACC Cardiovasc Interv. 2011 Nov;4(11):1255]. Jacc: Cardiovascular Interventions. 2011;4(9):974-81. Sep. [pmid: 21939937].
10 Faulknier BA, Broce M, Baskerville S, et al. Clinical outcomes following IVUS-guided stent deployment in a community hospital. Journal of Invasive Cardiology. Jun. 2004;16(6):311-15. [pmid: 15156000].
11 Fearon WF, Bornschein B, Tonino PA, et al. Economic evaluation of fractional flow reserve-guided percutaneous coronary intervention in patients with multivessel disease. Circulation. Dec. 14. 2010;122(24):2545-50. [pmid: 21126973].
12 Fitzgerald PJ, Oshima A, Hayase M, et al. Final results of the Can Routine Ultrasound Influence Stent Expansion (CRUISE) study. Circulation. Aug. 1. 2000;102(5):523-30. [pmid: 10920064].
13 Frey AW, Hodgson JM, Muller C, et al. Ultrasound-guided strategy for provisional stenting with focal balloon combination catheter: results from the randomized Strategy for Intracoronary Ultrasound-guided PTCA and Stenting (SIPS) trial. Circulation. Nov. 14. 2000;102(20):2497-502. [pmid: 11076823].
14 Fujimoto H, Tao S, Dohi T, et al. Primary and mid-term outcome of sirolimus-eluting stent implantation with angiographic guidance alone. Journal of Cardiology. Feb. 2008;51(1):18-24. [pmid: 18522771].
15 Gaster AL, Slothuus U, Larsen J, et al. Cost-effectiveness analysis of intravascular ultrasound guided percutaneous coronary intervention versus conventional percutaneous coronary intervention. Scandinavian Cardiovascular Journal. Mar. 2001;35(2):80-85. [pmid: 11405501].
16 Gaster AL, Slothuus SU, Larsen J, et al. Continued improvement of clinical outcome and cost effectiveness following intravascular ultrasound guided PCI: insights from a prospective, randomised study. Heart. Sep. 2003;89(9):1043-49. [pmid: 12923023].
17 Gerber RT, Latib A, Ielasi A, et al. Defining a new standard for IVUS optimized drug eluting stent implantation: the PRAVIO study. Catheterization & Cardiovascular Interventions. Aug. 1. 2009;74(2):348-56. [pmid: 19213067].
18 Gil RJ, Pawlowski T, Dudek D, et al. Comparison of angiographically guided direct stenting technique with direct stenting and optimal balloon angioplasty guided with intravascular ultrasound. The multicenter, randomized trial results. American Heart Journal. Oct. 2007;154(4):669-75. [pmid: 17892989].
19 Jakabcin J, Spacek R, Bystron M, et al. Long-term health outcome and mortality evaluation after invasive coronary treatment using drug eluting stents with or without the IVUS guidance. Randomized control trial. HOME DES IVUS. Catheterization & Cardiovascular Interventions. Mar. 1. 2010;75(4):578-83. [pmid: 19902491].
20 Kawata M, Okada T, Igarashi N, et al. Assessment of intravascular ultrasound-bearing balloon catheter-guided percutaneous transluminal coronary angioplasty and stenting. Heart & Vessels. 1997;(Suppl):12-17. [pmid: 9476578].
21 Kim JS, Hong MK, Ko YG, et al. Impact of intravascular ultrasound guidance on long-term clinical outcomes in patients treated with drug-eluting stent for bifurcation lesions: data from a Korean multicenter bifurcation registry. American Heart Journal. Jan. 2011;161(1):180-87. [pmid: 21167352].
22 Maluenda G, Lemesle G, Ben-Dor I, et al. Impact of intravascular ultrasound guidance in patients with acute myocardial infarction undergoing percutaneous coronary intervention. Catheterization & Cardiovascular Interventions. Jan. 1. 2010;75(1):86-92. [pmid: 19670305].
23 Mudra H, Di MC, de JP, et al. Randomized comparison of coronary stent implantation under ultrasound or angiographic guidance to reduce stent restenosis (OPTICUS Study). Circulation. Sep. 18. 2001;104(12):1343-49. [pmid: 11560848].
24 Mueller C, Mc Hodgson JB, Brutsche M, et al. Impact of intracoronary ultrasound guidance on long-term outcome of percutaneous coronary interventions in diabetics--insights from the randomized SIPS trial. Swiss Medical Weekly. Jun. 1. 2002;132(21-22):279-84. [pmid: 12362285].
25 Muramatsu T, Tsukahara R, Ho M, et al. Usefulness of fractional flow reserve guidance for PCI in acute myocardial infarction. Journal of Invasive Cardiology. Nov. 2002;14(11):657-62. [pmid: 12403892].
26 Nam CW, Yoon HJ, Cho YK, et al. Outcomes of percutaneous coronary intervention in intermediate coronary artery disease: fractional flow reserve-guided versus intravascular ultrasound-guided. Jacc: Cardiovascular Interventions. Aug. 2010;3(8):812-17. [pmid: 20723852].
27 Nasu K, Tsuchikane E, Awata N, et al. Quantitative angiographic and intravascular ultrasound study >5 years after directional coronary atherectomy. American Journal of Cardiology. Mar. 1. 2004;93(5):543-48. [pmid: 14996576].
28 Oemrawsingh PV, Mintz GS, Schalij MJ, et al. Intravascular ultrasound guidance improves angiographic and clinical outcome of stent implantation for long coronary artery stenoses: final results of a randomized comparison with angiographic guidance (TULIP Study). Circulation. Jan. 7. 2003;107(1):62-67. [pmid: 12515744].
29 Orford JL, Denktas AE, Williams BA, et al. Routine intravascular ultrasound scanning guidance of coronary stenting is not associated with improved clinical outcomes. American Heart Journal. Sep. 2004;148(3):501-06. [pmid: 15389239].
30 Ozaki Y, Yamaguchi T, Suzuki T, et al. Impact of cutting balloon angioplasty (CBA) prior to bare metal stenting on restenosis. Circulation Journal. Jan. 2007;71(1):1-8. [pmid: 17186970].
31 Park SJ, Hong MK, Lee CW, et al. Elective stenting of unprotected left main coronary artery stenosis: effect of debulking before stenting and intravascular ultrasound guidance. Journal of the American College of Cardiology. Oct. 2001;38(4):1054-60. [pmid: 11583882].
32 Park SJ, Kim YH, Park DW, et al. Impact of intravascular ultrasound guidance on long-term mortality in stenting for unprotected left main coronary artery stenosis. Circulation: Cardiovascular Interventions. Jun. 2009;2(3):167-77. [pmid: 20031713].
33 Pijls NH, Fearon WF, Tonino PA, et al. Fractional flow reserve versus angiography for guiding percutaneous coronary intervention in patients with multivessel coronary artery disease: 2-year follow-up of the FAME (Fractional Flow Reserve Versus Angiography for Multivessel Evaluation) study. Journal of the American College of Cardiology. Jul. 13. 2010;56(3):177-84. [pmid: 20537493].
34 Roy P, Steinberg DH, Sushinsky SJ, et al. The potential clinical utility of intravascular ultrasound guidance in patients undergoing percutaneous coronary intervention with drug-eluting stents. European Heart Journal. Aug. 2008;29(15):1851-57. [pmid: 18550555].
35 Russo RJ, Silva PD, Teirstein PS, et al. A randomized controlled trial of angiography versus intravascular ultrasound-directed bare-metal coronary stent placement (the AVID Trial). Circulation: Cardiovascular Interventions. Apr. 2009;2(2):113-23. [pmid: 20031704].
36 Sakamoto T, Kawarabayashi T, Taguchi H, et al. Intravascular ultrasound-guided balloon angioplasty for treatment of in-stent restenosis. Catheterization & Cardiovascular Interventions. Jul. 1999;47(3):298-303. [pmid: 10402282].
37 Schiele F, Meneveau N, Vuillemenot A, et al. Impact of intravascular ultrasound guidance in stent deployment on 6-month restenosis rate: a multicenter, randomized study comparing two strategies--with and without intravascular ultrasound guidance. RESIST Study Group. REStenosis after Ivus guided STenting. Journal of the American College of Cardiology. Aug. 1998;32(2):320-28. [pmid: 9708456].
38 Schiele F, Meneveau N, Seronde MF, et al. Medical costs of intravascular ultrasound optimization of stent deployment. Results of the multicenter randomized ‘REStenosis after Intravascular ultrasound STenting’ (RESIST) study. Int J Cardiovasc Intervent. Dec. 2000;3(4):207-13. [pmid: 12431345].
39 Seo T, Yamao K, Hayashi T, et al. Intravascular ultrasound in determining the end point of percutaneous transluminal coronary angioplasty. [Japanese]. Journal of Cardiology. Oct. 1996;28(4):183-89. [pmid: 8934333].
40 Talley JD, Mauldin PD, Becker ER, et al. Cost and therapeutic modification of intracoronary ultrasound-assisted coronary angioplasty. American Journal of Cardiology. Jun. 15. 1996;77(15):1278-82. [pmid: 8677866].
41 Tonino PA, De BB, Pijls NH, et al. Fractional flow reserve versus angiography for guiding percutaneous coronary intervention. New England Journal of Medicine. Jan. 15. 2009;360(3):213-24. [pmid: 19144937].
42 Wongpraparut N, Yalamanchili V, Pasnoori V, et al. Thirty-month outcome after fractional flow reserve-guided versus conventional multivessel percutaneous coronary intervention. American Journal of Cardiology. Oct. 1. 2005;96(7):877-84. [pmid: 16188509].
43 Yoshitomi Y, Kojima S, Yano M, et al. Benefit of intravascular ultrasound in Wiktor stent implantation. Catheterization & Cardiovascular Interventions. May. 1999;47(1):28-35. [pmid: 10385154].
44 Ioannidis JP, Ntzani EE, Trikalinos TA, et al. Replication validity of genetic association studies. Nat Genet. Nov. 2001;29(3):306-09. [pmid: 11600885].
45 Brennan JM, Peterson ED, Messenger JC, et al. Linking the National Cardiovascular Data Registry CathPCI Registry with Medicare claims data: validation of a longitudinal cohort of elderly patients undergoing cardiac catheterization. Circ Cardiovasc Qual Outcomes. Jan. 2012;5(1):134-40. [pmid: 22253370].