# Methods

Figure 2 is a flow chart depicting the process for the future research needs project, from invitation of stakeholders and dissemination of background materials through topic nomination and ranking (before, during, and after two Webinars), and development of research protocols for the final lists of future research needs topics. Details for each of the step are described below.

Figure 2 Future research needs process

Abbreviations: CER = comparative effectiveness review; EPC = evidence-based practice center; FRN = future research needs

Figure 2 is a flow chart depicting the process for the future research needs project, from invitation of stakeholders and dissemination of background materials through topic nomination and ranking (before, during, and after two Webinars), and development of research protocols for the final lists of future research needs topics.

## Approach to Evidence Gap Identification

We used an iterative process with a stakeholder panel to identify future research needs topics for prioritization. Based on the evidence gaps identified in the original CER (Table 1), we generated an initial list of FRN topics and then solicited additional topics from the stakeholder panel through teleconferences and emails. To make sure that we are not recommending new trials that are already being conducted elsewhere, on August 31, 2012, we searched ClinicalTrials.gov to find ongoing or recently completed trials relevant to the topic. Three randomized trials were identified.^b^

b The AVIO (NCT00936169) is a completed study from Italy, comparing IVUS versus angiography alone optimization of the use of drug-eluting stents. The results have not been published.

The FAVOR (NCT01175863) is an ongoing randomized trial being conducted in South Korea comparing the effectiveness of FFR-guided versus IVUS-guided PCI for the treatment of intermediate coronary lesions. The primary outcome of this trial is MACE; secondary outcomes are the individual components of MACE. Patients will be followed clinically for up to 2 years. This trial is expected to enroll 1400 patients and will be completed by January 2014.

The DEFER-DES (NCT00592228) was a randomized controlled trial from South Korea, comparing FFR-guided with angiography alone-guided stenting using drug-eluting stents in patients with intermediate coronary lesions. It has since been terminated owing to slow enrollment.

### Stakeholder Panel

We have adapted a Tufts-developed model of stakeholder engagement to identify individuals from seven stakeholder categories. This model was designed to build a panel representing the full range of stakeholders who may use research evidence in health care and public health decisionmaking.

1. Patients and the Public. This group represents current and potential consumers of patient-centered healthcare and population-focused public health. This group also includes caregivers, family members, and patient advocacy organizations, all of whom address the interests of consumers.
2. Providers. This group includes individuals (e.g., nurses, physicians, and other providers of care and support services) as well as organizations (e.g., hospitals, clinics, community health centers, community based organizations, pharmacies, emergency medical services (EMS) agencies, skilled nursing facilities) that provide care to patients and populations.
3. Purchasers. This group includes employers, the self-insured, government, and other entities responsible for underwriting the costs of health care.
4. Payers. This group represents insurers, Medicare and Medicaid, individuals with deductibles, and others responsible for reimbursement for interventions and episodes of care.
5. Product Makers. This group includes pharmaceutical and medical device manufacturers.
6. Policymakers. This group includes organizations such as the White House, Department of Health and Human Services, Congress, states, professional associations, and intermediary groups that collate and distribute information to policymakers.
7. Principal investigators, researchers, and research funders. Individuals representing these categories may wear several hats and may be responsible for different types of decisions. For example, some health care purchasers are also payers, and conversely some payers also provide care. Patients and their advocates may be providers or employers with policymaking responsibilities, and so on. In addition, each of these seven stakeholder types may be focused on applying research evidence at the patient- or population level. Patient-level decisions included questions regarding the best treatment for a given patient at a given time. Population-level decisions included questions regarding the optimal services, resources, policies, and alternatives for groups of patients and other communities connected by practice setting, geography, clinical domain, or other means. To be patient-centered, decisions made about groups of patients must recognize both the diversity of needs across populations and the heterogeneity of individuals within populations.

Because a future research needs project is intended to rank research questions by priority, product makers (i.e., manufacturers of intravascular diagnostic technology) were considered to be in potential conflict of interest. They were therefore restricted to participation in the topic nomination process but not in topic refinement or prioritization. Additionally, purchasers were considered to share the same perspective on this topic as would payers, and therefore were not invited to participate as a distinct group on the panel.

### Identification and Invitation of Individual Stakeholders

As part of the protocol development, we created an a priori target number of stakeholders representing each group in our proposed panel (Table 2), attempting to create a balance across stakeholder categories, and seeking to cover a range of technical and personal expertise in the group as a whole. We used these targets to identify individuals to serve on our panel through several means. We began by inviting individuals who have previously served in advisory roles for the EPC's intravascular diagnostic techniques CER. In addition, EPC team members were asked to identify professional contacts that could help us reach the targets for each of the target groups on the panel. Finally, we conducted searches on google.com and MEDLINE® to identify active intravascular diagnostic technique researchers for the provider and principal investigator categories.

Table 2 Stakeholders invited

Category | Subcategory | Number of Stakeholders
Patients and the public | Current patients | 2
Providers | Clinicians – interventional cardiologist | 5
Providers | Clinicians – noninterventional cardiologist | 5
Providers | Clinicians – nurse practitioner or physician assistant | 5
Providers | Hospital administrator | 5
Payers | Private insurer | 2
Payers | Medicare | 2
Policymakers | FDA (Food and Drug Administration) devices group | 1
Principal investigators/researchers | Health services | 1
TOTAL | | 11

An invitation letter was sent to individuals representing each of the final six target groups, and names were added to assemble a representative panel of nine nongovernment stakeholders plus two government stakeholders. All stakeholders completed a standard disclosure of interest form. Again, device makers (“product makers” in the 7Ps taxonomy) were invited to propose topics; they were not invited to participate in refinement or prioritization.

### Introduction of Process to the Stakeholder Panel

Along with an invitation letter, we distributed pertinent portions of the executive summary and the “Future Research” section of the original CER draft together with the protocol to the invited stakeholders. The original Key Questions, summary of evidence table, and the implications sections were highlighted in the executive summary. The purpose of the FRN project and the expectations for input from the stakeholders were outlined clearly in the invitation letter.

Soon after populating the panel, to accommodate everyone's schedule^c^, we conducted a first round of webinars with different stakeholders over a one week period to explain the purpose and process of the FRN topic development process and to review research gaps in intravascular diagnostic technology. For each nominated topic, stakeholders were also asked to provide a brief rationale to explain why they consider the topic to be a potential priority. When time permitted, we asked stakeholders to briefly describe related topics of interest.

c We also offered one-on-one conferences (e.g., patients only) on an as needed basis.

### Iterative Process To Identify Future Research Needs Topics

Based on the input from the first round of webinars, we reorganize the topic nomination document into separate topics based both on evidence gaps and additional topics suggested by the stakeholders. We also collated all the stakeholders' comments into their respective topics and distributed this document so everyone can be informed on what each other has opined.

A second round of webinars was held to allow stakeholders to voice further opinions about the nominated topics. Stakeholders were also encouraged to provide comments and feedback by email. We prepared minutes of calls and circulated to all participants.

The revisions to the document with the list of FRN topics were based on the discussions and continued on an iterative process.

## Approach to Prioritization

Stakeholders were asked to consider four dimensions of need related to the proposed topic. These four dimensions are drawn from the Effective Health Care (EHC) Program Selection Criteria (Appendix A). These dimensions and EHC program guidance were described in detail in the lead up to submission, discussion, and selection of FRN topics. They are:

- Importance
- Desirability of Research/Duplication
- Feasibility
- Potential Impact

A fifth dimension of the Selection Criteria, appropriateness, was not evaluated by the stakeholders, as AHRQ already deemed the topic of intravascular diagnostics to adequately meet this criterion. The EHC Program guidance on these criteria was explained in detail at each webinar encounter with the stakeholders. Please see Appendix A for a more complete description of AHRQ's EHC Program Selection Criteria.

## Approach to Stakeholder Engagement for Prioritization

With a final list of potential topics, stakeholders were asked to consider the previously mentioned four dimensions of need for each FRN topic by filling in a web form to evaluate each of the 12 nominated topics Stakeholders evaluated each topic as “low priority,” “low to intermediate priority,” “intermediate priority,” “intermediate to high priority,” or “high priority.”

The EPC ranked the FRN topics based on stakeholder responses to the survey. A count of the topics receiving a “high priority” mention was computed as well as the mean average score for all the topics. Three topics received high priority by more than half of those who participated. These three topics' research needs were further refined.

## Approach to Research Question Development and Considerations for Potential Research Designs

The EPC transformed the final list of FRN topics into answerable research questions using standard “PICOD” criteria (Population, Intervention, Comparator, Outcomes, study Design). When necessary, two or more alternative PICOD-based research proposals were offered, and the EPC discussed and described the pros and cons of these alternatives. The EPC specifically considered the feasibility of the research questions, focusing on potential sample size, time, and recruitment issues.

To determine candidate study designs, study feasibility, and sample size calculations, we followed the structure laid out in “Future Research Needs for the Comparison of Percutaneous Coronary Interventions with Bypass Graft Surgery in Nonacute Coronary Artery Disease,” written by our EPC (Tufts) as an example FRN document.^d^

d Trikalinos TA, Dahabreh IJ, Wong J, Rao M. Future Research Needs for the Comparison of Percutaneous Coronary Interventions with Bypass Graft Surgery in Nonacute Coronary Artery Disease: Identification of Future Research Needs from Comparative Effectiveness Review No. 9 [Internet]. Rockville (MD): Agency for Healthcare Research and Quality (US); 2010 Sep. http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=522.

Briefly: Candidate study designs will differ across types of research needs. Effectiveness or efficacy of treatments can be most definitively addressed in randomized trials, and secondarily in well-conducted nonrandomized comparative observational studies. In contrast, eliciting patient preferences can be meaningfully performed with nonexperimental designs (for example, in a survey). Furthermore, observational studies may be most appropriate to enhance generalizability and determine effectiveness, as opposed to efficacy alone. Each final FRN topic was assessed as to the context of the research question. A determination was made as to whether evaluation of efficacy or effectiveness is of greater need. This informed the choice of study design. Regardless of study design, a full set of PICO criteria (population, intervention, comparator, outcomes) was proposed.

Studies that do not require new data collection are in principle feasible, provided that access to existing data can be agreed upon or has already been granted. Analysis of an existing registry, standard meta-analysis, or meta-analysis of individual patient data can be conducted in a limited timeframe. The feasibility of such studies, generally, does not depend on the desired sample size. The feasibility of trials (or other studies requiring collection of primary data) may not be feasible if it were too expensive or complex to conduct, if it would require too long a followup, or if it would rely on information or data that is not yet available or would be difficult to obtain. When randomized trials were deemed to be the most appropriate study design to address an FRN topic, we performed sample size calculations using standard formulae for a two-sided chi-squared test at the 0.05 level of significance. We also estimated the true relative effect between intervention and control. We assumed an allocation ratio of 1:1, no loss to followup, no crossover between treatments, and no sequential monitoring.

As needed, the EPC consulted with individual stakeholders for assistance in making decisions regarding appropriate study designs.