# Executive Summary

## Background

Coronary artery disease (CAD), is a narrowing (stenosis) of one or more of the epicardial coronary arteries. It is most commonly due to the buildup of plaque (atherosclerosis), which impedes the ability of these blood vessels to deliver oxygenated blood to the heart muscle (myocardium). Revascularization of the stenotic vessel either by dilatation using a balloon (also known as angioplasty) or by using a bypass venous graft (also known as coronary bypass) are the most common methods to restore blood supply. Percutaneous coronary intervention (PCI) or angioplasty with stent deployment is currently the most commonly performed revascularization procedure for CAD.

PCI has traditionally been based on qualitative and quantitative coronary angiography (visual inspection of the radiocontrast lumenogram and computer-based quantification, respectively), an imaging technique for visualizing the interior of blood vessels. While angiography is the standard technique for anatomic visualization of coronary arteries, it is not without limitations as it does not provide information about what is causing the narrowing or whether the narrowing seriously impedes blood flow. Several adjunctive intravascular diagnostic procedures and imaging techniques (collectively referred to as intravascular diagnostic techniques in this report) have been developed for the purpose of providing more detailed anatomic and hemodynamic information about lesions in coronary arteries. However, whether this additional information improves patient outcomes and whether this improvement outweighs any risks introduced by the additional procedure needs to be considered.

The current Future Research Needs (FRN) project was launched upon the completion of an Agency for Healthcare Research and Quality (AHRQ) comparative effectiveness review (CER) on intravascular diagnostic techniques, and builds on the evidence gaps identified in that review. The CER found 37 studies that directly compared patient outcomes for different techniques. The two techniques that were considered in these studies were fractional flow reserve (FFR) and intravascular ultrasound (IVUS). FFR is a physiologic technique that measures pressure difference using a guide wire across a coronary artery stenosis; it is the ratio between pressure after and pressure before a coronary artery stenosis under conditions of maximum cardiac blood flow (higher ratio suggests less impediment to blood flow across the stenosis). IVUS is an imaging technique that depicts the nature of the atheromatous plaques and the anatomy of the artery wall. All of the studies that aimed to determine which lesions require stenting involved FFR, while most of the studies that looked at optimizing stent placement (i.e., stent size and dilation) involved IVUS. Using criteria based on the AHRQ CER Methods Guide (www.ncbi.nlm.nih.gov/books/NBK47095), we assessed the strength of evidence for major comparisons of interest, as follows:

- There is a moderate strength of evidence (drawn from one randomized controlled trial [RCT] and one nonrandomized study) that the adjunctive use of FFR during stenting, as compared with angiography alone, to decide whether an intermediate coronary lesion (50 to 70% stenosis) requires stenting, can confer a lower risk of composite endpoint of death or myocardial infarction (MI) or of major adverse cardiac event (MACE), decrease procedural costs, and lead to fewer stent implantations. However, these FFR studies also included patients with low risk lesions and lower grades of angina, and excluded left main coronary artery disease and acute MI.
- There is a moderate strength of evidence (drawn from 9 RCTs and 22 nonrandomized studies) that supports no significant difference in mortality and MI, but a significant reduction in restenosis and repeat revascularizations with IVUS-guided stenting compared with stent placement guided by angiography alone. This significant reduction was observed in RCTs, but not observed in nonrandomized comparative studies. Notably, most of the RCTs were conducted before 2000 using previous generation bare-metal stents.
- There is insufficient evidence concerning the use of any intravascular diagnostic techniques immediately after PCI to evaluate the success of stent placement as compared with angiography, or for direct comparisons between intravascular diagnostic techniques.
- There is a moderate strength of evidence (on the basis of one large-sample-size nonrandomized study) that sex, diabetes mellitus status, lesion length and reference diameter, and interaction with IVUS- and angiography-guided stent placement did not show any significant association with individual components of death or MI or the composite outcome of MACE.
- There is insufficient evidence to evaluate the comparative effect of techniques other than FFR and IVUS on outcomes.

The present report describes the development of a stakeholder-prioritized list of research needs for that topic, along with a measured consideration of the advantages and disadvantages of various potential research designs, in order to help researchers and funders develop future research proposals or solicitations.

The evidence gaps identified in the intravascular diagnostic techniques CER are summarized in Table A, organized and labeled by Key Question and PICOD (Population, Intervention, Comparator, Outcome, study Design) category. These gaps limited the conclusions that could be drawn in the original CER, and thus became the initial list of priority topics for the present FRN project. Figure A depicts the analytic framework used to guide the Key Questions for the CER.

Table A Evidence gaps affecting conclusions for the Key Questions

Key Question | PICO Categories | Evidence Gap
1 | Population | For the comparison between FFR-guided stenting or other intravascular diagnostic techniques and stenting guided by angiography alone:
1 | Population | Because the included studies enrolled a large proportion (>75%) of male patients with lower grades of angina, there is an evidence gap comparing the use of FFR-guided PCI with angiography-guided PCI in female patients and in patients with more serious diseases like LMD or acute MI.
1 | Intervention | There is an overall evidence gap for this comparison because there were only 3 comparative studies on FFR.
1 | Comparator | There is an evidence gap comparing patients with low angina score who are potentially eligible to receive aggressive medical therapy instead of PCI to patients who will receive stenting guided by adjunctive FFR, other intravascular diagnostic techniques, or angiography alone.
1 | Outcome | There is an evidence gap for within 30-day outcomes because the single RCT only reported periprocedural MI, but did not provide data for in-hospital death, repeat revascularizations, or composite endpoint of MACE.
1 | General evidence gap | There is an overall evidence gap for this comparison because no studies compared the use of other intravascular diagnostic techniques besides FFR and angiography.
2 | Population | For the comparison between IVUS (intravascular ultrasound)-guided stent placement and stenting guided by angiography alone:
2 | Population | The vast majority of included studies enrolled a large proportion (>75%) of male patients and all but one RCT specifically excluded patients with LMD or acute MI. Therefore, there is an evidence gap comparing the use of IVUS-guided PCI with angiography-guided PCI in female patients and in patients with more serious diseases like LMD or acute MI.
2 | Intervention | There is a lack of IVUS trial data on the influence of operator's choice of balloon size and inflation pressures and their impact on clinical outcomes.
2 | Comparator | Because only two studies (both RCTs) conducted after year 2000 used the newer and current drug-eluting stents, there is an evidence gap concerning the use of newer types of stents.
2 | Outcome | There is an evidence gap concerning long-term outcomes since neither RCT reported data on cardiac mortality and few studies reported outcomes greater than 1 year.
2 | General evidence gap | There is an overall evidence gap for this comparison because no studies compared the use of other intravascular diagnostic techniques besides IVUS and angiography.
3 | General evidence gap | On the impact of using an intravascular diagnostic technique or angiography to evaluate the success of stenting immediately after the procedure: There is an evidence gap because only two observational studies (both with a high risk for bias) addressed this question.
4 | General evidence gap | Comparing different intravascular diagnostic techniques: There is an evidence gap because only one observational study with a high risk for bias addressed this question comparing IVUS with FFR.
5 | General evidence gap | Subgroups of interest: No studies evaluated additional subgroups of interest, including patients with and without diabetes, patients with chronic inflammation (e.g., systemic lupus erythematosus), and patients with atherosclerosis following heart transplantation. There is an evidence gap in terms of lack of reporting of subgroup analyses of patients who underwent intravascular diagnostic-guided PCI compared with angiography-guided PCI and their impact on outcomes.

Abbreviations: FFR = Fractional flow reserve; IVUS = intravascular ultrasound; LMD = left main coronary disease; MACE = major adverse cardiac event; MI = myocardial infarction; PCI = percutaneous coronary intervention; PICO = population, intervention, comparator, outcome; RCT = randomized controlled trial

Figure A Analytic framework

Abbreviations: CAD = coronary artery disease; KQ = Key Question; MACE = major adverse cardiac events; MI = myocardial infarction; QoL = quality of life

Figure A is an analytic framework that depicts the events that individuals experience while undergoing evaluation of coronary artery disease and treatment with revascularization, including medical therapy, coronary artery bypass grafting, and percutaneous coronary intervention with stenting. The framework includes the following: Patient Population of Interest, Treatment, Imaging and diagnostic techniques, Therapeutic decisionmaking, Surrogate Outcome Measures, Stent-related Outcomes, Clinical Outcomes and Adverse Effects of Treatment. Our patient population of interest is patients with coronary artery disease. The treatment is coronary stenting. Imaging and diagnostic techniques are intravascular adjunctive techniques (referred here as intravascular diagnostic techniques) and angiography. The intermediate outcome measures are utilized to determine if the treatment is effective and include minimal lumen diameter, reference diameter, and percent diameter stenosis. Clinical outcomes include death (any cause or cardiac), myocardial infarction, repeat revascularization, major adverse cardiac event, quality of life/satisfaction with treatment, and survival. Adverse effects include procedural complications, and stent-related outcomes include stent thrombosis and binary restenosis.

## Methods

### Identifying and Engaging a Stakeholder Panel

We followed a recently developed taxonomy that was designed to aid researchers in the identification, recruitment, and engagement of stakeholders.1 Based on an a priori categorization of stakeholders according to type, we convened a panel consisting of two patients, four providers, two payers, one policymaker, and one researcher. The stakeholders were provided with the executive summary of the intravascular diagnostics CER and went through a formal orientation process.

### Identifying Evidence Gaps and Developing PICOD for Each Gap

As the authors of the intravascular diagnostic techniques CER, we generated the initial list of FRN topics based on the Research Needs section of the report, and then organized the list of evidence gaps according to Key Questionss and PICOD elements. Participating panelists reviewed the preliminary topics and used an iterative process to identify additional FRN topics through webinars and emails.

### Criteria for Prioritizing Evidence Gaps

Stakeholders were asked to consider four dimensions of need. These four dimensions are outlined in the Effective Health Care (EHC) Program Selection Criteria and consist of: (1) importance, (2) desirability of research/avoidance of unnecessary duplication, (3) feasibility, and (4) potential impact. The fifth dimension of the EHC program selection criteria, appropriateness, was not evaluated by the stakeholders, as AHRQ had already deemed the topic of intravascular diagnostics to adequately meet this criterion.

### Approach to Prioritization

Following two rounds of Webinar discussions and email communication, the topic list was finalized. Stakeholders were asked to rate each of the proposed FRN topics according to the pertinent EHC Program criteria.

### Developing Research Questions

We transformed the final list of FRN topics into research questions using standard PICOD criteria. We discussed various alternatives for future research efforts aimed at answering each question, specifically considering the feasibility of addressing the research questions with respect to the study design, potential sample size, the time required, recruitment, and ethical issues.

## Results

The FRN identification process led to the nomination of 12 topics (Table B). The three topics where more than 50 percent of the stakeholders had selected them as high priority constitute the highest priority FRN topics. Two topics (one on the use of intravascular physiologic measurements like FFR in treatment decisionmaking before stenting; one on the impact of the use of intravascular imaging diagnostics such as IVUS on stenting) are based directly on evidence gaps identified in the CER. Although the evidence for the topic on intravascular physiologic measurements was rated to be of moderate strength, the stakeholders felt more research was needed for a number of reasons. First, as evidence currently rests primarily on one RCT, there is the possibility that future studies will not support the favorable effect of FFR-guided stenting. Second, given the widespread use of stents (with associated harms and costs) and the well documented variation in practice, any technology that can better target risks and benefits could have a major impact on patient outcomes and healthcare costs. As such it is important to fully explore dimensions beyond what is covered in existing trials.

Table B Prioritized topics for future research needs in intravascular diagnostics, compared with angiography alone

Topic^*^ | Topic Questions | Number of Stakeholders Who Think This Is a High-Priority Topic | Mean
Prioritized Future Research Needs Topics
1 | What is the impact on clinical outcomes of a treatment decision (medical therapy, stent, or bypass) made on the basis of the adjunctive use of intravascular physiologic diagnostics, as compared with angiography alone? | 7 | 4.67
2 | In patients in whom there is already a precatheterization indication for stenting, what is the impact on stenting parameters (e.g., which lesion to stent, type of stent, stent length) and clinical outcomes of the use versus non-use of intravascular diagnostics? | 6 | 4.44
3 | Once the decision has been made to place a stent, what is the impact on clinical outcomes of the adjunctive use of intravascular imaging diagnostics, such as IVUS or OCT, in stent placement and stent optimization, as compared with angiography alone? | 5 | 4.22
Other Topics
4 | What is the impact on clinical outcomes of a treatment decision (medical therapy, stent, or bypass) made on the basis of the adjunctive use of intravascular imaging diagnostics, such as IVUS or OCT, as compared with angiography alone? | 4 | 4.11
5 | What is the impact of baseline characteristics (e.g., sex, age, co-morbidities, type of lesions, severity of disease) on clinical outcomes when using intravascular diagnostics during coronary stenting, as compared with angiography alone? | 4 | 4.00
6 | What is the impact on clinical outcomes of operator experience, as measured by the number of completed procedures in using intravascular diagnostics? | 4 | 3.78
7 | What is the impact on clinical outcomes of a treatment decision (medical therapy, stent, or bypass) made on the basis of the adjunctive use of intravascular physiologic diagnostics, as compared with other intravascular diagnostics? | 3 | 3.67
8 | What is the impact on clinical outcomes of a treatment decision (medical therapy, stent, or bypass) made on the basis of the adjunctive use of intravascular imaging diagnostics, such as IVUS or OCT, as compared with FFR? | 3 | 3.67
9 | What adverse events and complications have been associated with the use of intravascular diagnostic procedures for coronary stenting, as compared with angiography alone? | 2 | 3.44
10 | Once the decision has been made to place a stent, what is the impact on clinical outcomes of the adjunctive use of intravascular imaging diagnostics, such as IVUS or OCT, during stenting and stent optimization, as compared with other intravascular diagnostics such as FFR? | 2 | 3.22
11 | What is the impact on clinical outcomes of the adjunctive use of new and on-the-horizon or hybrid intravascular diagnostics, as compared with angiography alone or other established techniques such as FFR or IVUS? | 2 | 3.33
12 | What is the impact on therapeutic decisionmaking and clinical outcomes of the use of intravascular diagnostics in patients who were discovered to have no evidence of coronary artery disease by angiography (such as in patients examined due to intense coronary vasospasm)? | 2 | 3

Abbreviations: FFR = fractional flow reserve; IVUS = intravascular ultrasound; OCT = optical coherence tomography

* Prioritized topics (1–12) are listed in the order they were prioritized by the stakeholder panel.

For the second topic on imaging diagnostics, there is a lack of data on the use of IVUS, as compared with angiography alone, to evaluate placement of newer types of stents including bioabsorbable ones. The third topic on the added value of intravascular diagnostic techniques in patients for whom there is already a clear clinical or other non-invasive diagnostic indication (e.g., a high-risk positive stress perfusion scan, a noninvasive imaging technique that demonstrated large areas of decreased blood flow in the heart) suggesting the need for revascularization was raised by the stakeholders.

In research comparing clinical interventions, RCTs are the optimal study design, but ethical and feasibility concerns can make this methodology difficult or impossible to justify. An RCT to address the first topic—the adjunctive use of intravascular diagnostic techniques like FFR—for instance, would be difficult to conduct as FFR-guided PCI is already becoming the standard of care in patients with borderline and intermediate lesions. Therefore, to address this topic, an observational design is a feasible alternative. An observational study could be used to compare the outcomes of treatment decision made on the basis of FFR versus no FFR, if established methodological approaches like matching, propensity score analyses, and other techniques, are used to adjust for baseline differences between groups.

For the second topic on the adjunctive use of intravascular diagnostic techniques in patients with a clear clinical or other noninvasive diagnostic indication suggesting the potential need for revascularization (stenting or coronary bypass graft), because IVUS and FFR serve different purposes (IVUS helps to optimize stenting parameters like stent lengths, stent inflation pressure, and others; FFR helps to define the need for stenting and which lesions to stent), we propose different study designs depending on the particular intravascular diagnostic modality.

For IVUS, we propose a pragmatic trial of use versus nonuse of IVUS to examine the impact on stenting parameters and clinical outcomes. For FFR, an RCT comparing the use versus nonuse of FFR-guided angiography in patients with high-risk positive stress test may be difficult to conduct as FFR-guided PCI is fast becoming the standard of care. Therefore, an observational study design is recommended for FFR.

Similarly, in those with a negative stress test and the presence of classic symptom complex, as providers may use IVUS and/or FFR to help make a determination on the need for stenting, it would also be difficult to recruit providers and patients for an RCT in this setting. In this setting, we therefore propose a prospective observational study design, using a combination of catheterization registry data that are derived directly from electronic health records, linked with Medicare claims and state mortality records. Treatment assignment would be non-random, but statistical techniques could be used to adjust for potential confounding from treatment selection.

For the third topic on how the adjunctive use of intravascular diagnostic techniques affects stenting, a pragmatic RCT comparing the use of intravascular diagnostics versus angiography alone on stenting parameters and clinical outcomes would help to fill in the evidence gaps. Observational studies may also help to fill in the gap but existing registries like the CathPCI database do not have enough details on stenting parameters to help address these questions (e.g., the impact of intravascular diagnostic techniques on stent “optimization” and clinical outcomes). A novel module could be implemented in the CathPCI registry to collect additional IVUS parameters and additional stenting parameters. These data could be used to assess how IVUS influenced the procedure.

## Discussion

The use of intravascular diagnostics in patients being considered for percutaneous coronary artery stenting is a highly technical topic and requires considerable domain knowledge to appreciate how these adjunctive diagnostics aid traditional coronary artery catheterization and stenting. Added to this difficulty is the challenge of defining optimal stent placement; this concept has permeated the clinical community but standards have not been established.

To identify priority future research needs we sought and successfully incorporated insight from clinical experts as well as from insurance, hospital, patient and policy experts. Additionally, we have asked domain experts to review the description of the technical details concerning these diagnostic devices, to assure that it is faithful to the complex clinical details of intravascular diagnostic technology as applied to cardiovascular disease.

## Conclusions

This report identifies three high-priority future research needs with regards to intravascular diagnostic techniques, as determined by a stakeholder panel. They are:

1. What is the impact on clinical outcomes of a treatment decision (medical therapy, stent, or bypass) made on the basis of the adjunctive use of intravascular physiologic diagnostics, as compared with angiography alone?
2. In patients in whom there is already a clear clinical and other non-invasive diagnostic indication suggesting the need for revascularization (stenting or coronary artery bypass graft), what is the impact on stenting parameters (e.g., which lesion to stent, type of stent, stent length) and clinical outcomes of the use versus non-use of intravascular diagnostics in those undergoing stenting?
3. Once the decision has been made to place a stent, what is the impact on clinical outcomes of the adjunctive use of intravascular imaging diagnostics, such as IVUS or OCT, in stent placement and stent optimization, as compared with angiography alone?

In summary, both data from pragmatic randomized controlled trials and properly adjusted observational studies could be used to fill in these gaps and help address these important clinical questions.