# Acknowledgments

The authors gratefully acknowledge the stakeholders for their contributions to this project.

## Contributors

- J. Matthew Brennan, M.D., M.P.H.
  Division of Cardiovascular Disease
  Duke University Medical Center
  Durham, NC
- Marylou Depeiza
  Patient representative
  Boston, MA
- Anton B. Dodek, M.D.
  Quality and Consultative Support
  Blue Cross Blue Shield of Massachusetts
  Boston, MA
- Anne Pelikan
  Patient representative
  Ipswich, MA
- Deeb N. Salem, M.D.
  Department of Medicine
  Tufts University School of Medicine
  Boston, MA
- Ashwini Sastry, M.D.
  Office of Device Evaluation
  Interventional Cardiology Devices Branch
  Food and Drug Administration
  Silver Spring, MD
- Jyme Schafer, M.D.
  Centers for Medicare and Medicaid Services
  Baltimore, MD
- Donald S. Shepard, Ph.D.
  The Heller School for Social Policy and Management
  Brandeis University
  Waltham, MA
- Monvadi B. Srichai-Parsia, M.D., FAHA, FACC
  Department of Radiology and Medicine
  NYU School of Medicine
  New York, NY
- Sergio Waxman, M.D.
  Tufts University School of Medicine
  Boston, MA
- Adam Zucker, M.D.
  Center for Devices and Radiological Health
  Food and Drug Administration
  Silver Spring, MD