# Conclusion

This report identifies three high-priority future research needs with regards to intravascular diagnostic techniques, as determined by a stakeholder panel. They are:

1. What is the impact on clinical outcomes of a treatment decision (medical therapy, stent, or bypass) made on the basis of the adjunctive use of intravascular physiologic diagnostics, as compared with angiography alone?
2. In patients in whom there is already a clear clinical and other noninvasive diagnostic indication suggesting the need for revascularization (stenting or coronary artery bypass graft), what is the impact on stenting parameters (e.g., which lesion to stent, type of stent, stent length) and clinical outcomes of the use versus non-use of intravascular diagnostics in those undergoing stenting?
3. Once the decision has been made to place a stent, what is the impact on clinical outcomes of the adjunctive use of intravascular imaging diagnostics, such as IVUS or OCT, in stent placement and stent optimization, as compared with angiography alone?

In summary, both data from pragmatic randomized controlled trials and properly adjusted observational studies could be used to fill in these gaps and help address these important clinical questions.