# Background

Coronary artery disease (CAD), is a narrowing (stenosis) of one or more of the epicardial coronary arteries. It is most commonly due to the buildup of plaque (atherosclerosis), which impedes the ability of these blood vessels to deliver oxygenated blood to the heart muscle (myocardium). Revascularization of the stenotic vessel either by dilatation using a balloon (also known as angioplasty) or by using a bypass venous graft (also known as coronary bypass) are the most common methods to restore blood supply. Percutaneous coronary intervention (PCI) or angioplasty with stent deployment is currently the most commonly performed revascularization procedure for CAD.

PCI has traditionally been based on qualitative and quantitative coronary angiography (visual inspection of the radiocontrast lumenogram and computer-based quantification, respectively), an imaging technique for visualizing the interior of blood vessels. While angiography is the standard technique for anatomic visualization of coronary arteries, it is not without limitations as it does not provide information about what is causing the narrowing or whether the narrowing seriously impedes blood flow. Several adjunctive intravascular diagnostic procedures and imaging techniques (collectively referred to as intravascular diagnostic techniques in this report) have been developed for the purpose of providing more detailed anatomic and hemodynamic information about lesions in coronary arteries. However, whether this additional information improves patient outcomes and whether this improvement outweighs any risks introduced by the additional procedure has yet to be determined.

The current Future Research Needs (FRN) project was launched upon the completion of an Agency for Healthcare Research and Quality (AHRQ) comparative effectiveness review (CER) on intravascular diagnostic techniques,2 and builds on the evidence gaps identified in that review. The present report describes the development of a stakeholder-prioritized list of research needs for that topic, along with a measured consideration of the advantages and disadvantages of various potential research designs, in order to help researchers and funders develop future research proposals or solicitations.

## Scope of CER

The 2013 CER upon which the current FRN report is based, “Intravascular Diagnostic Procedures and Imaging Techniques Versus Angiography Alone,” was sponsored by the Agency for Healthcare Research and Quality and conducted by the Tufts Evidence-based Practice Center (EPC).2 It reviewed pertinent publications through May 2012 and addressed five Key Questions:

Key Question 1. In patients with CAD, what is the impact of using an intravascular diagnostic technique and angiography in deciding whether a coronary lesion requires stenting—when compared with angiography alone—on therapeutic decisionmaking, and intermediate and patient-centered outcomes?

Key Question 2. For patients undergoing PCI, what is the impact of using an intravascular diagnostic technique and angiography to guide the stenting procedure (either immediately prior to or during the procedure)—when compared with angiography-guided stenting—on therapeutic decisionmaking, and intermediate and patient-centered outcomes?

Key Question 3. For patients having just undergone a PCI with stenting, what is the impact of using an intravascular diagnostic technique and angiography to evaluate the success of stenting immediately after the procedure—when compared with angiography alone—on therapeutic decisionmaking, and intermediate and patient-centered outcomes?

Key Question 4. How do different intravascular diagnostic techniques compare with each other in their effects on therapeutic decisionmaking, and intermediate and patient-centered outcomes?

a. During diagnostic coronary angiography for the evaluation of the presence/extent of CAD and the potential need for coronary intervention?
b. During PCI to guide stenting?
c. Immediately after PCI to evaluate the success of stenting?

Key Question 5. What factors (e.g., patient/physician characteristics, availability of prior noninvasive testing, type of PCI performed) influence the effect of intravascular diagnostic technique and angiography—when compared with angiography (or among different intravascular diagnostic technique techniques)—on therapeutic decisionmaking, and intermediate and patient-centered outcomes?

a. During coronary angiography for the evaluation of the presence/extent of CAD and the potential need for coronary stenting
b. During PCI to guide stenting
c. Immediately after PCI to evaluate the success of stenting

Therapeutic decisionmaking outcomes outlined in the Key Questions were defined as follows:

- Key Question 1: In patients with CAD, the change in the number of hemodynamically significant lesions after the application of intravascular diagnostic, and the change in the decision about an interventional therapy (e.g., if stenting is needed) after the application of intravascular diagnostic technique
- Key Question 2: During PCI, the change in the type of stent or number of stents or length of stent after the application of intravascular diagnostic technique
- Key Question 3: Immediately after PCI, the need for additional stenting modifications

## CER Study Selection and Outcomes of Interest

Each question had specific criteria for study inclusion based on the PICOD (Population, Intervention, Comparator, Outcomes, and Design) categorization. We included studies conducted in adults (≥18 years of age) with CAD who were being considered for PCI with stenting. All forms of CAD presentation were included. Coronary angiography was the comparison of interest for Key Questions 1, 2, 3, and 5. For Key Question 4, head-to-head comparisons of two or more intravascular diagnostic techniques were examined. For Key Question 5, the modifiers of treatment effect included patient/physician characteristics, availability of prior noninvasive testing, and the type of PCI performed.

Outcomes of interest included therapeutic decisionmaking; patient-centered outcomes (e.g., mortality and cardiovascular events); intermediate outcomes (e.g., minimal lumen diameter, percent diameter stenosis, and stent-related outcomes [e.g. restenosis, stent thrombosis]). They were further categorized on the basis of timing of followup: in-hospital outcomes, short-term outcomes (discharge to 30 days), medium-term outcomes (>30 days to 1 year), and long-term outcomes (>1 year).

## Findings of the CER

In total, 37 unique studies (in 41 published articles) met eligibility criteria.3-43 The two most commonly evaluated intravascular diagnostic techniques were intravascular ultrasound (IVUS) and fractional flow reserve (FFR). Findings are as follows:

- For Key Question 1, there was moderate evidence (drawn from one randomized controlled trial [RCT] and one nonrandomized study) that the use of FFR in deciding whether a coronary lesion requires stenting, as compared with angiography-guided stenting, can confer a lower risk of composite endpoint of death or myocardial infarction (MI) or of major adverse cardiac events (MACE), decrease procedural costs, and lead to fewer stents implantations.
- For Key Question 2, there was moderate evidence (drawn from 9 RCTs and 22 nonrandomized studies) that fails to support a statistically significant difference in most clinical and intermediate outcomes between IVUS-guided and angiography-guided stenting patient groups.^a^
  a For followup up to 1 year in randomized trials, a lower risk of repeat revascularization (summary relative risk: 0.70; 95% CI [0.51, 0.97]) but a higher risk of mortality (summary relative risk: 1.84; 95% CI [0.88, 3.85]) in the IVUS group was observed, compared with the angiography group. Any observed significant differences in intermediate outcomes were small and inconsistent.
- For Key Questions 3 and 4, there was insufficient evidence (two nonrandomized studies of small sample size, rated as being at high risk of bias) concerning the use of intravascular diagnostic techniques immediately after PCI to evaluate the success of stenting as compared with angiography-guided stenting, or for direct comparisons between intravascular diagnostic techniques.
- For Key Question 5, there was moderate evidence (on the basis of one nonrandomized study of 9,070 patients) that any interaction of sex, diabetes mellitus status, lesion length or reference diameter with IVUS- and angiography-guided stenting did not have significant association with individual components or composite outcome of MACE. With the exception of IVUS and FFR, there was insufficient evidence to evaluate the comparative effect of any other intravascular diagnostic techniques on the outcomes of interest.

## Identification of Evidence Gaps

The current FRN project was undertaken in order to address the evidence gaps in the literature with regards to intravascular diagnostic techniques and their comparative effectiveness, identified during the synthesis of the aforementioned CER. Table 1 summarizes the evidence gaps identified in our review of intravascular diagnostic techniques (listed in no particular order).

Table 1 Evidence gaps inferred from CER findings

Key Question | PICO Categories | Evidence Gap
1 | Population | For the comparison between FFR-guided stenting or other intravascular diagnostic techniques and stenting guided by angiography alone:
1 | Population | Because the included studies enrolled a large proportion (>75%) of male patients with lower grades of angina, there is an evidence gap comparing the use of FFR-guided with angiography-guided PCI in female patients and in patients with more serious diseases like LMD or acute MI.
1 | Intervention | There is an overall evidence gap for this comparison because there were only 3 comparative studies on FFR.
1 | Comparator | There is an evidence gap comparing patients with low angina score who are potentially eligible to receive aggressive medical therapy instead of PCI to patients who will receive stenting guided by adjunctive FFR, other intravascular diagnostic techniques, or angiography alone.
1 | Outcome | There is an evidence gap for within 30-day outcomes because the single RCT only reported periprocedural MI, but did not provide data for in-hospital death, repeat revascularization, or MACE.
1 | General evidence gap | There is an overall evidence gap for this comparison because no studies compared the use of other intravascular diagnostic techniques besides FFR and angiography.
2 | Population | For the comparison between IVUS-guided stent placement and stenting guided by angiography alone:
2 | Population | The vast majority of included studies enrolled a large proportion (>75%) of male patients and all but one RCT specifically excluded patients with LMD or acute MI. Therefore, there is an evidence gap comparing the use of IVUS-guided with angiography-guided PCI in female patients and in patients with more serious diseases like LMD or acute MI.
2 | Intervention | There is a lack of IVUS trial data on the influence of operator's choice of balloon size and inflation pressures and their impact on clinical outcomes.
2 | Comparator | Because only two studies (both RCTs) conducted after year 2000 used the newer and current drug eluting stents, there is an evidence gap concerning the use of newer types of stents.
2 | Outcome | There is an evidence gap concerning long-term outcomes since neither RCT reported data on cardiac mortality and few studies reported outcomes greater than 1 year.
2 | General evidence gap | There is an overall evidence gap for this comparison because no studies compared the use of other intravascular diagnostic techniques besides IVUS and angiography.
3 | General evidence gap | On the impact of using an intravascular diagnostic technique and angiography to evaluate the success of stenting immediately after the procedure: There is an evidence gap because only two observational studies and with high risk of bias reported on this comparison.
4 | General evidence gap | Comparing different intravascular diagnostic techniques: There is an evidence gap because only one observational study and with high risk of bias reported on this comparison (IVUS vs. FFR).
5 | General evidence gap | Subgroups of interest: No studies evaluated additional subgroups of interest, including patients with and without diabetes, patients with chronic inflammation (e.g., systemic lupus erythematosus), and patients with atherosclerosis following heart transplantation. There is an evidence gap in terms of lack of reporting of subgroup analyses of patients who underwent intravascular diagnostic-guided PCI compared with angiography-guided PCI and their impact on outcomes.

Abbreviations: FFR = Fractional flow reserve; IVUS = intravascular ultrasound; LMD = left main disease; MACE = major adverse cardiac event; MI = myocardial infarction; PCI = percutaneous coronary intervention; PICO = population, intervention, comparator, outcome; RCT = randomized controlled trial

## Analytic Framework

The analytic framework (Figure 1) depicts the logical interconnection of all five Key Questions addressed by the CER. It maps the Key Questions within the context of the populations of interest, the interventions, comparator, and the outcomes of interest, and the chain of reasoning that the evidence must support to link the interventions to improved health outcomes. The figure illustrates how the additional application of intravascular diagnostic techniques (compared with angiography alone) may aid treatment decisionmaking during diagnostic angiography (A in the figure), allow procedure optimization during PCI (B), and assessment of immediate results in patients undergoing PCI to decide the need for additional procedures (C), and improve short-term (in hospital or discharge to 30 days), medium-term (≥30 days to 1 year), and long-term (>1 year) outcomes. Angiography alone is the comparator for Key Questions 1–3. For Key Question 4, the comparator is a different intravascular diagnostic technique from the index intravascular diagnostic technique of interest (head-to-head comparisons of intravascular diagnostic techniques). For Key Question 5, potential effect modifiers of treatment effects were examined, for both comparisons between angiography with and without intravascular diagnostic technique and comparisons of two or more intravascular diagnostic techniques. For Key Question 5, the modifiers of treatment effect included patient/physician characteristics, availability of prior noninvasive testing, and the type of PCI performed.

Figure 1 Analytic framework

Abbreviations: CAD = coronary artery disease; KQ = Key Question; MACE = major adverse cardiac events; MI = myocardial infarction; QoL = quality of life

Figure 1 is an analytic framework that depicts the events that individuals experience while undergoing evaluation of coronary artery disease and treatment with revascularization, including medical therapy, coronary artery bypass grafting, and percutaneous coronary intervention with stenting. The framework includes the following: Patient Population of Interest, Treatment, Imaging and diagnostic techniques, Therapeutic decisionmaking, Surrogate Outcome Measures, Stent-related Outcomes, Clinical Outcomes and Adverse Effects of Treatment. Our patient population of interest is patients with coronary artery disease. The treatment is coronary stenting. Imaging and diagnostic techniques are intravascular adjunctive techniques (referred here as intravascular diagnostic techniques) and angiography. The intermediate outcome measures are utilized to determine if the treatment is effective and include minimal lumen diameter, reference diameter, and percent diameter stenosis. Clinical outcomes include death (any cause or cardiac), myocardial infarction, repeat revascularization, major adverse cardiac event, quality of life/satisfaction with treatment, and survival. Adverse effects include procedural complications, and stent-related outcomes include stent thrombosis and binary restenosis.