# Acronyms

AHRQ: Agency for Healthcare Research and Quality
CABG: Coronary artery bypass graft surgery
CAD: Coronary artery disease
CER: Comparative Effectiveness Review
CMS: Centers for Medicare and Medicaid Services
EHC: Effective Health Care
EPC: Evidence-based Practice Center
EMS: Emergency Medical Services
FDA: Food and Drug Administration (U.S.)
FFR: Fractional flow reserve
FRN: Future Research Needs
IVUS: Intravascular ultrasound
KQ: Key Question
LMD: Left main (coronary artery) disease
MACE: Major adverse cardiac event
MI: Myocardial infarction
NCDR: National Cardiovascular Data Registry
OCT: Optical coherence tomography
PCI: Percutaneous coronary intervention
PICOD: Population, Intervention, Comparator, Outcome, study Design
QCA: Quantitative coronary angiography
RCT: Randomized controlled trial
STEMI: ST-segment elevation myocardial infarction
TEP: Technical Expert Panel
TLR: Target lesion revascularization
TOO: Task Order Officer