# Results

## Literature Search Update

The literature search update captured 107 studies published since August 1, 2011. A table of primary studies, new abstracts, and ongoing clinical trials deemed relevant to the research needs and research questions is provided in Appendix D.

### Research Needs

The orientation calls to each member of the Stakeholder Panel were conducted between May 14 and 18, 2012. The first teleconference with all the Stakeholders occurred in two sessions: the first with four Stakeholders participating on May 21, 2012, and the second with six Stakeholders participating on May 29, 2012. Two Stakeholders participated in both calls. A total of nine research needs (see Appendix E) were identified through a combination of the CER findings and input from the Stakeholder panel. During the first teleconference, the Stakeholders reviewed the preliminary list of nine research needs, made the suggestion that they be more detailed rather than generic, and also discussed possible future research questions and study designs.

After the first teleconference, the Stakeholders completed the online SurveyMonkey^®^, ranking their top three research needs from the list of nine, using the revised EHC program selection criteria previously described. The response rate was 100 percent (n=8). Total scores ranged from 11 to 3, with a single item receiving no votes and a score of 0. The results of the first survey are provided in Appendix F.

A second teleconference was held on June 14, 2012, to discuss the results of the Stakeholders’ prioritization of the research needs and to solicit input on research questions. Again, to accommodate the busy schedules of participants, calls were made at two separate times, with four Stakeholders participating in a morning session and three in an afternoon session (a total of 6 of 8 Stakeholders participated; the remaining two provided followup input in one-on-one calls with the team leader).

Based on an evaluation of scores, there was no single, clear cut-off point on which to distinguish high- from low-priority items. In the teleconference discussion, the Stakeholder Panel used an empirical approach to establish this cut-off, based on the observation that a logical progression for a diagnostic assay like PCA3 was to move from an understanding of the clinical validity of the signal to informed applications of its use in decisionmaking followed by either a chain of evidence or direct evidence suggesting a positive impact on long-term health outcomes.

The top-ranked research needs were as follows:

- Research Need 1: Lack of information on the comparative performance of PCA3 and currently used biomarkers to detect prostate cancer; lack of “matched studies” on comparisons;
- Research Need 8: Lack of studies on how PCA3 actually helps in treatment decisionmaking;
- Research Need 5: Lack of information on the impact of PCA3 on short-term outcomes, such as biopsy decisionmaking; and
- Research need 6: Uncertainty of impact of PCA3 in biopsy decisionmaking on long-term health outcomes.

Based on their empirical approach, the Stakeholders suggested combining Research Needs 5 and 8 into one item addressing decisionmaking and including Research Need 6 as the final item determining the impact of PCA3 testing on long-term health outcomes.

The resulting three top-ranked research needs were as follows:

- Research Need 1: Lack of information on the comparative performance of PCA3 and currently used biomarkers to detect prostate cancer; lack of “matched studies” on comparisons;
- Research Need 2: Lack of studies on how PCA3 actually helps in biopsy or treatment decisionmaking; and
- Research Need 3: Uncertainty of the impact of PCA3 in biopsy decisionmaking on long-term health outcomes.

Research Need 1 addresses the diagnostic accuracy of PCA3 in comparison to other tests for prostate cancer. In the PCA3 CER, the most common comparison observed was between PCA3 and tPSA. A small number of articles described PCA3 compared to percent-free PSA or to nomograms; however, the information was either low in quality or insufficient to draw conclusions about the relative performance of these tests.

Research Need 2 addresses how understanding the aggressiveness of identified or missed tumors might be used in decisionmaking about whether to biopsy or defer and follow the patient over time, or used to determine whether a patient should be offered active surveillance versus aggressive therapy.

Research Need 3 addresses the critical question of whether PCA3 testing has an impact on long-term health outcomes. To the extent that PCA3 testing reduces the need for biopsy or identifies aggressive tumors that warrant treatment, the assay has the potential to increase benefits and reduce harms. The panel recognized that this research need might be difficult to address, but concluded that test accuracy alone would not necessarily equate to test effectiveness.

### Research Questions

Research questions for each of the research needs were generated from the PCA3 CER and input from the Stakeholder Panel. Relevant research questions were the subject of discussion at both teleconferences as Stakeholders considered mechanisms for addressing the important research needs identified. Based on a Stakeholder suggestion, one research question was added to the original three from the CER for Research need 1, but none were added to the original two questions for Research Need 2 or the one question for Research Need 3.

Once the final list of research questions was compiled, Stakeholders again completed an online SurveyMonkey^®^ to prioritize the research questions (see Appendix G). Because of the well-established hierarchal approach provided by the Stakeholders, the prioritization of research questions was modified to rate questions within each research need, rather than to generically evaluate these questions collectively across the research needs.

For Research Need 1, there were a total of four research questions, and each Stakeholder ranked the top three of most importance. For Research Need 2, the Stakeholders ranked the two questions in order of perceived importance. Research Need 3 had only one research question and was, therefore, not included for prioritization. The prioritization results for the research questions for Research Needs 1 and 2 are presented in Appendix H.

For Research Need 1, the three highest priority research questions were as follows:

- Research Question 1.2: What is the comparative effectiveness of PCA3 compared to the two commonly used add-on tests of fPSA and tPSA velocity/doubling time in predicting prostate biopsy results?
- Research Question 1.1: What are PCA3’s diagnostic performance characteristics in patients with elevated tPSA levels?
- Research Question 1.3: What is the comparative effectiveness of PCA3 compared to externally validated nomograms in predicting prostate biopsy results?

For Research Need 2, both research questions were ranked equally, and therefore remained in the following order:

- Research Question 2.1: What information does PCA3 provide about the aggressiveness of prostate cancer? Do positive results correlate to tumors with aggressive features on biopsy or upgrading of tumors on prostatectomy? Do negative results correlate to tumors that may not require identification or aggressive treatment?
- Research Question 2.2: Does the addition of PCA3, either alone, or in combination with other markers, change prostate cancer biopsy or treatment decisionmaking for the patient or physician?

The final three research needs, in priority order, along with the associated prioritized research questions and PICOTS are presented in Table 2.

Table 2 Priority PCA3 research needs with research questions and PICOTS

Rank | Research Need | Preliminary Research Questions | Population | Intervention | Comparator | Outcome | Timing | Setting
1 | Lack of information on the comparative performance of PCA3 and currently used biomarkers to detect prostate cancer; lack of “matched studies” on comparators | 1. What is the comparative effectiveness of PCA3 compared to the two commonly used add-on tests of fPSA and tPSA velocity/doubling time in predicting prostate biopsy results? | Patients at risk for prostate cancer based on elevated PSA and/or abnormal DRE | PCA3 testing | fPSA and PSA velocity/doubling time | Positive biopsy | Any duration of followup will be evaluated. | All settings
1 | Lack of information on the comparative performance of PCA3 and currently used biomarkers to detect prostate cancer; lack of “matched studies” on comparators | 2. What are PCA3’s diagnostic performance characteristics in patients with elevated tPSA levels? | Patients at risk for prostate cancer based on elevated PSA and/or abnormal DRE | PCA3 testing | tPSA | Positive biopsy | Any duration of followup will be evaluated | All settings
1 | Lack of information on the comparative performance of PCA3 and currently used biomarkers to detect prostate cancer; lack of “matched studies” on comparators | 3. What is the comparative effectiveness of PCA3 compared to externally validated nomograms in predicting prostate biopsy results? | Patients at risk for prostate cancer based on elevated PSA and/or abnormal DRE | PCA3 testing | Externally validated nomograms | Positive biopsy | Any duration of followup will be evaluated | All settings
2 | Lack of studies on how PCA3 actually helps in biopsy or treatment decisionmaking^a^ | 1. What information does PCA3 provide about the aggressiveness of prostate cancer? In other words, do positive results correlate to tumors with aggressive features on biopsy or upgrading of tumors on prostatectomy? Do negative results correlate to tumors that may not require identification or aggressive treatment? | Patients with elevated PCA3 values | PCA3 testing | Current standard of care without PCA3 testing | Features of aggressive tumor on biopsy; upgrading of tumor on prostatectomy | Any duration of followup will be evaluated | All settings
2 | Lack of studies on how PCA3 actually helps in biopsy or treatment decisionmaking^a^ | 2. Does the addition of PCA3, either alone, or in combination with other markers, change prostate cancer biopsy or treatment decisionmaking for the patient or physician? | Patients with PCA3 values available for making decisions about biopsy or decision to apply active surveillance versus aggressive therapy | PCA3 testing | Current standard of care without PCA3 testing | Decision to biopsy or wait; decision to initiate aggressive therapy or to elect to be followed with active surveillance | Any duration of followup will be evaluated | All settings
3 | Uncertainty of impact of PCA3 in biopsy decisionmaking on long-term health outcomes | 1. Does addition of PCA3 testing change long-term health outcomes in prostate screening? | Patients electing to be screened for prostate cancer using PSA and/or digital rectal exam | PCA3 testing | Current standard of care without PCA3 testing | Mortality, morbidity, quality of life | Any duration of followup will be evaluated | All settings

Abbreviations: DRE = digital rectal examination; fPSA = free prostate-specific antigen; PCA3 = prostate cancer antigen 3 gene; PICOTS = population, interventions, comparators, outcomes, timing, setting; PSA = prostate-specific antigen; tPSA = total prostate-specific antigen

a This gap includes lack of information on the correlation between PCA3 results and tumor aggressiveness, which is critical in understanding how decisions will be made.

## Study Designs

The PCA3 FRN team considered and evaluated a number of study designs to address the priority research needs and their associated research questions.

For the assessment of study designs for Research Need 1, the appropriateness of using diagnostic accuracy,12,13 prospective - retrospective studies using archived samples,14 and case control studies15,16 to assess diagnostic performance of PCA3 were evaluated.

For the assessment of the impact of PCA3 testing on decisionmaking (Research Need 2), the study designs proposed differed for the two research questions. For Research Question 2.1, which focuses on tumor aggressiveness, rather than just the detection of tumors alone, the study designs were the same as those described for Research Need 1, Research Questions 1.1–1.3.

Research Question 2.2 addresses the issue of whether the magnitude of changes in prediction for biopsy outcomes provided by PCA3 impacts clinical decisionmaking. In this case, three kinds of studies of physician/patient response to test results were evaluated: randomized clinical trial, prospective cohort study, and physician/patient survey.

For the assessment of the impact of PCA3 testing on long-term health outcomes (Research Need 3), the appropriateness of the randomized clinical trial, prospective cohort study, and modeling were evaluated.

The specific research designs to address each research need and research question are described below and are included in Tables 3 through 6.

Table 3 Study design evaluations for PCA3 Research Need 1, Research Questions 1.1–1.3

Study Design Considerations | Diagnostic Accuracy Study | Prospective-Retrospective Study | Case Control Study
Description of design | PCA3 compared to currently used tests (tPSA, free PSA, PSA velocity, externally validated nomograms without PCA3; externally validated nomograms including PCA3); clinical performance (sensitivity, specificity, positive and negative predictive values) assessed and reported in matched comparisons to a biopsy gold standard. Results of PCA3 are blinded and not used in decisionmaking. | PCA3 measured in archived samples from patients identified as biopsy-positive or biopsy-negative in a population resembling the intended use population. Not possible because of lack of urine specimen banks, but as noted in the Future Research Needs for Comparative Effectiveness of Treatments of Localized Prostate Cancer,17 such banks are needed. | Samples from patients predefined as positive or negative for cancer are selected; testing is performed in these samples.
Advantages of study design for producing a valid result | Studies are usually cross-sectional or involve short-term followup only. Data to support this type of study may already exist, but have been incompletely analyzed and reported. | Uses available resources and data, but care must be taken to avoid incorrect handling of samples and incomplete data. | Allows use of convenience samples; results may not mimic real world use, and estimates of both sensitivity and specificity must be interpreted with extreme care.
Resource use, size, and duration | Study requires patient recruitment and informed consent with samples collected with active intervention (attentive digital rectal exam), special processing and then testing using PCA3 and correlation of results with standard testing against a biopsy gold standard. Followup or further diagnostic evaluation is not usually required. Currently, no good models exist for addressing verification bias and, therefore, data interpretation may be challenging. | Less resource-intensive and shorter than a randomized clinical trial. There may be costs associated with obtaining and using samples and data. | Less resource intense than a diagnostic accuracy study or a well performed retrospective study using repository samples reflecting the intended use population.
Ethical, legal and social issues | Minimal; the test is approved for use by FDA, for repeat biopsies. The test is not currently a practice of care standard, and so blinding should pose no dilemma. | Minimal; studies must be performed with attention to patient confidentiality and privacy. | Minimal; studies must be performed with attention to patient confidentiality and privacy.
Availability of data or ability to recruit | This is a high volume test process and burden of disease is high. Recruitment of subjects should not be difficult although future studies should learn from the comparative effectiveness review and pay more attention to the quality of data being collected. | This is currently very problematic in that urine repositories for patients subject to prostate cancer are not available. | This is currently problematic in that urine repositories for patients subject to prostate cancer are not available.

Abbreviations: FDA = U.S. Food and Drug Administration; PCA3 = prostate cancer antigen 3 gene; PSA = prostate-specific antigen; tPSA = total prostate-specific antigen

Note:

1.1 What is the comparative effectiveness of PCA3 compared to the two commonly used add-on tests of fPSA and tPSA velocity/doubling time in predicting prostate biopsy results?
1.2 What are PCA3’s diagnostic performance characteristics in patients with elevated tPSA levels?
1.3 What is the comparative effectiveness of PCA3 compared to externally validated nomograms in predicting prostate biopsy results?

Table 4 Study design evaluations for PCA3 Research Need 2, Research Question 2.1: What information does PCA3 provide about the aggressiveness of prostate cancer?

Study Design Considerations | Diagnostic Accuracy Study | Prospective-Retrospective Study | Case Control Study
Description of design | PCA3 compared to currently used tests (tPSA, free PSA, PSA velocity, externally validated nomograms without PCA3; externally validated nomograms including PCA3); clinical performance (sensitivity, specificity, positive and negative predictive values) assessed and reported in matched comparisons to a biopsy gold standard including information characterizing tumor aggressiveness. This can be based on biopsy findings that suggest aggressive versus indolent tumor behavior, such as the Epstein criteria, or can be based on changes in grading in patients with positive biopsy who go on to be treated by prostatectomy. Results of PCA3 are blinded and not used in decisionmaking. | PCA3 measured in archived samples from patients identified as biopsy-positive or biopsy-negative in a population resembling the intended use population. Not possible because of lack of urine specimen banks, but as noted in Future Research Needs for Comparative Effectiveness of Treatments of Localized Prostate Cancer17 such banks are needed. | Patients predefined as positive or negative for cancer with measures of aggressiveness characterized are selected; testing is performed in these samples.
Advantages of study design for producing a valid result | Although information collected is similar to that for questions 1.1–1.3, more detailed information on results are sought allowing for information on whether identified/missed tumors are clinically significant or not. | Uses available resources and data, but care must be taken to avoid incorrect handling of samples and incomplete data. | Allows use of convenience samples; results may not mimic real world use, and estimates of both sensitivity and specificity must be interpreted with extreme care.
Resource use, size, and duration | Study requires patient recruitment and informed consent with samples collected with active intervention (attentive digital rectal exam), special processing and then testing using PCA3 and correlation of results with standard testing against a biopsy gold standard. Followup or further diagnostic evaluation is not required and so study efforts and costs are least burdensome. | Less resource-intense and shorter than a randomized clinical trial. There may be costs associated with obtaining and using samples and data. | Less resource-intense and shorter than a prospective study or a well-performed retrospective study using repository samples reflecting the intended use population.
Ethical, legal and social issues | Minimal; the test is approved for use by FDA, but is not currently a practice of care standard and so blinding should pose no dilemma. | Minimal; studies must be performed with attention to patient confidentiality and privacy. | Minimal; studies must be performed with attention to patient confidentiality and privacy.
Availability of data or ability | This is a high volume test process and burden of disease is high (although its impact controversial). Recruitment of subjects should not be difficult although future studies should learn from the comparative effectiveness review and pay more attention to the quality of data being collected. | This is currently very problematic in that urine repositories for patients subject to prostate cancer are not available. | This is currently problematic in that urine repositories for patients subject to prostate cancer are not available.

Abbreviations: FDA = U.S. Food and Drug Administration; PCA3 = prostate cancer antigen 3 gene; PSA = prostate-specific antigen; tPSA = total prostate-specific antigen

Table 5 Study design evaluations for PCA3 Research Need 1, Research Question 2.2: Does the addition of PCA3, either alone or in combination with other markers, change prostate cancer biopsy or treatment decisionmaking for the patient or physician?

Study Design Considerations | Randomized Clinical Trials | Prospective Cohort Study | Physician/Patient Survey
Description of design | Patients at risk for prostate cancer (initial or repeat biopsy) based on elevated tPSA and/or abnormal DRE or with positive biopsies are randomized to receive PCA3 in addition to standard testing or standard testing alone. Biopsies performed versus deferred and the yield of positive and negative results in the two arms are compared, and evidence of patients with aggressive versus indolent disease in the two arms is also compared. Features of aggressiveness can be enhanced by including studies that use standardized criteria linking results to clinical outcomes using published or unpublished, but public, information as available. In order to assess impact on patients choosing active surveillance versus aggressive therapy, experiments could be designed to add PCA3 to on-going studies of active surveillance. In addition, different PCA3 values could be compared to grading changes between biopsy and prostatectomy. | Patients with and without prostate cancer identified in an intended use population and tracked according to PCA3 status --tested or not tested, positive or negative test results). Patients followed prospectively to determine choices about biopsy and treatment. | Hypothetical scenarios for test use can be developed and evaluated in physicians or patients to determine how they might use information in comparison to current standard of care. To develop a meaningful survey, it is necessary to have good information on test performance and to consider how decision aids might be used to maximize use of testing information provided in such a survey.
Advantages of study design for producing a valid result | With proper inclusion and exclusion criteria and careful recording of results, this should provide a clear indication of how results will be used in decisionmaking and will also provide information on the outcomes of testing—how many cancers identified and what type (indolent or aggressive). | Baseline characteristics can be measured, but may not be balanced. Statistical techniques may be able to partially control potential bias. | There is a growing interest in the use of conjoint analysis to determine how medical information is used to affect management choices. Although the approach is new, it appears able to provide valuable information toward understanding how information might be used.
Resource use, size, and duration | This is likely to be a resource-intense process. Since the study is focused only on immediate decisionmaking and biopsy results, long -term followup would be interesting, but not essential, to answer the questions raised. | Resource use, size, and duration are likely to be similar to that of a randomized clinical trial. | Less resource intensive and shorter than a prospective study.
Ethical, legal and social issues | Minimal; although the test has been approved by FDA for repeat biopsy (previous negative biopsy patients), there is no information on health care outcomes, hence the need for study. | Minimal; although the test has been approved by FDA for repeat biopsy (previous negative biopsy patients), there is no information on health care outcomes, hence the need for study. | None. This type of survey presents no ethical, legal, or social issues.
Availability of data or ability to recruit | Biopsy or treatment choice is commonly encountered in urological practice; the area is one of considerable physician and patient interest; recruitment would be expected to be relatively straightforward. | Biopsy or treatment choice is commonly encountered in urological practice; the area is one of considerable physician and patient interest; recruitment would be expected to be relatively straight forward. | This is an area of considerable interest to both physicians and patients; recruitment should be relatively straightforward.

Abbreviations: DRE = digital rectal examination FDA = U.S. Food and Drug Administration; PCA3 = prostate cancer antigen 3 gene; PSA = prostate-specific antigen; tPSA = total prostate-specific antigen

Table 6 Study design evaluations for PCA3 Research Need 3, Research Question 3.1: Does addition of PCA3 testing change long-term health outcomes in prostate screening?

Study Design Considerations | Randomized Clinical Trials | Prospective Cohort Study | Modeling
Description of design | Patients at risk for prostate cancer (initial or repeat biopsy) based on elevated tPSA and/or abnormal DRE or with positive biopsies are randomized to receive PCA3 in addition to standard testing or standard testing alone. Long-term outcomes, including morbidity, mortality and quality of life followed over 10 to 20 years. | Patients with and without prostate cancer identified in an intended use population and tracked according to PCA3 status --tested or not tested, positive or negative test results).Patients followed prospectively to determine choices about biopsy and treatment. | Estimates of outcomes would be made based on what is known about the natural history of prostate cancer and what is learned through the studies in Research Question 2.1 about likely behavior of cancers diagnosed or treated using information from PCA3 testing.
Advantages of study design for producing a valid result | The gold standard for understanding health care outcomes occurring as a result of use of PCA3 testing. Clinical characteristics can be carefully balanced. | Baseline characteristics can be measured, but may not be balanced. Statistical techniques may be able to partially control potential bias. | Modeling allows predictions of outcomes from use of PCA3 based on logical assumptions of tumor behavior and known impact of interventions. However, the strength of the model will depend on the reliability of the assumptions made. While it is possible that informed decisions will be made based on this modeling, the validity will not be well established. Technique has been used by the United States Preventive Services Task Force in developing some recommendations.
Resource use, size, and duration | This is likely to be a resource-intense process of large size, long duration, and high cost. Compliance may be a problem if diagnostic and therapeutic choices change during the duration of the study. | Resource use, size, and duration are likely to be similar to that of a randomized clinical trial. Compliance may be a problem if diagnostic and therapeutic choices change during the duration of the study. | Likely to be less resource-intense than other approaches.
Ethical, legal and social issues | Minimal; although the test has been approved by FDA for repeat biopsy (previous negative biopsy patients), there is no information on health care outcomes, hence the need for study. | Minimal; although the test has been approved by FDA for repeat biopsy (previous negative biopsy patients), there is no information on health care outcomes, hence the need for study. | None.
Availability of data or ability to recruit | Biopsy or treatment choice is commonly encountered in urological practice; the area is one of considerable physician and patient interest; recruitment would be expected to be relatively straightforward. | Biopsy or treatment choice is commonly encountered in urological practice; the area is one of considerable physician and patient interest; recruitment would be expected to be relatively straightforward. | This is an area of considerable interest to both physicians and statisticians; this would be a fertile area of collaboration.

Abbreviations: DRE = digital rectal examination FDA = U.S. Food and Drug Administration; PCA3 = prostate cancer antigen 3 gene; PSA = prostate-specific antigen; tPSA = total prostate-specific antigen

### Study Design Evaluation

Research Need 1: Lack of information on the comparative performance of PCA3 and currently used biomarkers to detect prostate cancer; lack of “matched studies” on comparators.

- Research Question 1.1: What is the comparative effectiveness of PCA3 compared to the two commonly used add-on tests of fPSA and tPSA velocity/doubling time in predicting prostate biopsy results?
- Research Question 1.2: What are PCA3’s diagnostic performance characteristics in patients with elevated tPSA levels?
- Research Question 1.3: What is the comparative effectiveness of PCA3 compared to externally validated nomograms in predicting prostate biopsy results?

Table 3 provides the study design evaluations for Research Questions 1.1–1.3, which were combined because they require the same basic approach. In each, the objective is to determine the comparative performance of PCA3 against the current standard of care by establishing diagnostic accuracy for each test of interest.

An ideal study to establish diagnostic accuracy would be to identify a large cohort of men being screened for prostate cancer (most commonly based on elevated PSA and/or abnormal DRE). All positive patients would be tested for analytes of interest: tPSA (repeated to assess regression to the mean), free PSA, PSA velocity, nomograms etc. All men would undergo biopsy to allow for a head to head comparison of PCA3 to currently used tests. Although it is unlikely everyone would be biopsied, as many as possible should be biopsied and reasons for dropout carefully described. It is important to note that this information was uniformly absent from studies of PCA3.

This ideal study, like most studies in the current literature, should be of matched design (comparative biomarkers are measured in the same individuals in the same setting allowing each individual to be a self-control). The data should be subject to matched analyses (e.g., McNemers test), stratified by biopsy-positive and biopsy-negative subgroups. Although all of the studies in this CER were matched, none of them were subject to a matched analysis.

It is important to note that although matched analysis is missing from the current literature on PCA3, most studies were performed using a matched design. It might be possible for individual investigators or groups of investigators to re-analyze existing data to better understand test performance. To the extent current reports have information on biopsy yield and reasons for drop-out, the ideal study may be approximated using existing data

While prospective-retrospective studies can sometimes be used to establish performance of a test using banked samples in patients with well-established demographic and clinical information, this is not possible for PCA3 testing at this time. While there are a number of biobanks of blood from patients studied for prostate cancer, no similar banks of stored urine are known to exist. Case control studies allow for testing in patients with established disease and in controls without disease. While this approach has the advantage that it often facilitates identification of samples for study, this design does not provide testing in the intended-use population, has a high risk of bias, and is generally reserved for exploratory studies only.

Research Need 2: Lack of studies on how PCA3 actually helps in biopsy or treatment decisionmaking.

- Research Question 2.1: What information does PCA3 provide about the aggressiveness of prostate cancer? In other words, do positive results correlate to tumors with aggressive features on biopsy or upgrading of tumors on prostatectomy? Do negative results correlate to tumors that may not require identification or aggressive treatment?

Table 4 provides the study design evaluation for Research Question 2.1 which, like the four research questions for Research Need 1, focuses on establishing the diagnostic accuracy of the PCA3 test. However, this question differs from the first three research questions by having as its endpoint the detection of indolent versus aggressive disease. Ideally, aggressiveness would be carefully defined, either using standard techniques established for biopsy (i.e., the Epstein criteria) or using information obtained by comparing biopsy results with staging results in menundergoing radical prostatectomy. Again a predefined cutoff would be selected, and test performance for predicting indolent or aggressive disease described in terms of diagnostic performance of clinical sensitivity, specificity, and predictive value of positive and negative results.

- Research Question 2.2: Does the addition of PCA3, either alone or in combination with other markers, change prostate cancer biopsy or treatment decisionmaking for the patient or physician?

Table 5 provides the study design evaluation for Research Question 2.2, which addresses the issue of whether the magnitude of changes in prediction for biopsy outcomes provided by PCA3 are significant enough to cause physicians or patients to make changes in either biopsy or treatment decisions. The goal of the research question would be to determine if the trade-off between reduction in biopsies and missed cancers could be communicated to physicians or patients in a manner that would allow for more informed decisions and improved outcomes.

While an optimal manner of looking at this issue would be by performing a randomized clinical trial looking at management decisions with and without use of PCA3, alternative techniques might be to perform a prospective cohort study or to use surveys or conjoint analysis to approximate decisionmaking in the face of varying test performance. Surveys or conjoint analyses are predicated on having good data about the comparative performance of the prognostic tools currently available, and would only be as reliable as performance estimates derived from data provided to answer research questions 1.1–1.3 and 2.1.

Research Need 3: Uncertainty of impact of PCA3 in biopsy decisionmaking on long-term health outcomes.

Research Question 3.1: Does addition of PCA3 testing change long-term health outcomes in prostate screening?

Table 6 provides the study design evaluations for Research Question 3.1, which focuses on the bottom line: Does PCA3 testing change long-term health outcomes? The gold standard for making this determination would be to perform a randomized controlled clinical trial, comparing management of patients with and without PCA3 and following a large number of patients over long periods of time to determine actual impact of testing on morbidity, mortality, and quality of life. An alternative would be a prospective cohort study. Stakeholders recognized the challenges such studies would present; however, as one Stakeholder noted, accuracy of testing does not assure effectiveness of testing.

A possible alternative or interim process for establishing the merit of PCA3 testing as an intervention might be a careful evaluation of the prognostic impact of the test, followed by an effort to establish a chain of evidence to support testing. There was vigorous discussion of formal modeling as a mechanism to replace the need for more formal short- or long-term trials, but concerns were raised about the assumptions that would need to be made. Missed tumors should exhibit the same or more indolent behavior than those identified by testing; the ability of testing to reduce biopsies or to detect clinically significant tumors should not be a result of confounding by demographic characteristics in patient subgroups (age, ethnic background, family history, etc.). Shorter-term studies similar to the REDUCE trial have already been used to study PCA3 performance,18,19 but could be replicated or expanded to better understand how the test impacts outcomes. The suggestion was also made to piggyback PCA3 testing on current trials studying active surveillance, similar to the recent report by Tosoian,5 but with more detail on outcomes (prostatectomy results) and longer term followup.