# References

1 Jemal A, Siegel R, Xu J, et al. Cancer statistics, 2010. CA Cancer J Clin. Sep–Oct. 2010;60(5):277-300. [pmid: 20610543].
2 Freedland SJ. Screening, risk assessment, and the approach to therapy in patients with prostate cancer. Cancer. Mar. 15. 2011;117(6):1123-35. [pmid: 20960523].
3 Yin M, Bastacky S, Chandran U, et al. Prevalence of incidental prostate cancer in the general population: A study of healthy organ donors. J Urol. Mar. 2008;179(3):892-5. discussion 5. [pmid: 18207193].
4 Sutcliffe P, Hummel S, Simpson E. Use of classical and novel biomarkers as prognostic risk factors for localised prostate cancer: A systematic review. Health Technol Assess. 2009;13:1-260.
5 Tosoian J, Loeb S. PSA and beyond: the past, present, and future of investigative biomarkers for prostate cancer. Scientific World J. 2010;10:1919-31. [pmid: 20890581].
6 Moyer VA. Screening for Prostate Cancer: U.S Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2012. May. 21.
7 Draisma G, Boer R, Otto SJ, et al. Lead times and overdetection due to prostate-specific antigen screening: estimates from the European Randomized Study of Screening for Prostate Cancer. J Natl Cancer Inst. 2003;95(12):868-78. [pmid: 12813170].
8 Bussemakers MJ, van Bokhoven A, Verhaegh GW, et al. DD3: a new prostate-specific gene, highly overexpressed in prostate cancer. Cancer Res. Dec. 1. 1999;59(23):5975-9. [pmid: 10606244].
9 Whitlock EP, Lopez SA, Chang S, et al. AHRQ Series Paper 3: Identifying, selecting, and refining topics for comparative effectiveness systematic reviews: AHRQ and the Effective Health-Care program. J Clin Epidemiol. 2010;63:491-501. [pmid: 19540721].
10 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for determining research gaps during systematic reviews. Methods Future Research Needs Report No. 2. (Prepared by the Johns Hopkins University Evidence-based Practice Center under Contract No. HHSA 290-2007-10061-I.) AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011.
11 Carey T, Sanders G, Viswanathan M, et al. Framework for Considering Study Designs for Future Research Needs. Methods Future Research Needs Paper No. 8. (Prepared by the RTI–UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I.) AHRQ Publication No. 12-EHC048-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
12 Bossuyt PM, Reitsma JB, Bruns DE, et al. Towards complete and accurate reporting of studies of diagnostic accuracy: the STARD initiative. Standards for Reporting of Diagnostic Accuracy. Clin Chem. Jan. 2003;49(1):1-6. [pmid: 12507953].
13 Bossuyt PM, Reitsma JB, Bruns DE, et al. The STARD statement for reporting studies of diagnostic accuracy: explanation and elaboration. Clin Chem. Jan. 2003;49(1):7-18. [pmid: 12507954].
14 Simon RM, Paik S, Hayes DF. Use of archived specimens in evaluation of prognostic and predictive biomarkers. J Natl Cancer Inst. 2009;101(21):1446-52. [pmid: 19815849].
15 Coates RJ, Kolor K, Stewart SL, et al. Diagnostic markers for ovarian cancer screening: Not ready for routine clinical use. Clin Cancer Res. 2008;13:7575. [pmid: 18948387].
16 Visintin I, Feng Z, Longton G, et al. Diagnostic markers for early detection of ovarian cancer. Clin Cancer Res. Feb. 15. 2008;14(4):1065-72. [pmid: 18258665].
17 Mauger B, Rothenberg B, Marbella A, et al. Future Research Needs for Comparataive Effectiveness of Treatments for Localized Prostate Cancer. Future Research Needs Paper No. 4. (Prepared by Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under contract No. 290-2007-10058-1). AHRQ Publication No. 10-EHC072-EF. Rockville, MD. Agency for Healthcare Research. September. 2010. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
18 Aubin SM, Reid J, Sarno MJ, et al. PCA3 molecular urine test for predicting repeat prostate biopsy outcome in populations at risk: Validation in the placebo arm of the dutasteride REDUCE trial. J Urol. Nov. 2010;184(5):1947-52. [pmid: 20850153].
19 Aubin SM, Reid J, Sarno MJ, et al. Prostate cancer gene 3 score predicts prostate biopsy outcome in men receiving dutasteride for prevention of prostate cancer: results from the REDUCE trial. Urology. Aug. 2011;78(2):380-5. [pmid: 21820580].
20 Cooperberg MR, Carroll PR, Klotz L. Active surveillance for prostate cancer: progress and promise. J Clin Oncol. 2011;29:3669-76. [pmid: 21825257].